# Appendix I—Comprehensive Care Flow Charts

Point of Entry: Alcohol and Other Drug Treatment

Patients | Assessment [image] | Medical Withdrawal and Treatment [image] | | | | | Refer for Prenatal Care
All Pregnant, Substance-Using Women | Drug Use/Abuse; - History; - Duration of use; - Frequency, type, amount; - Routes of administration; - Social context of use; - Past treatment; - Support group involvement; - Consequences; - Relapse factors; - Motivation for treatment/continued use; - Refer for prenatal care; Psychosocial; - Family history; - Support system; - Attitudes about pregnancy; - Education; - Employment; - Abuse: physical, emotional, sexual; - Legal; - Current crises; - Relationship to other children; Mental Health; - Mental status; - Psychiatric symptoms; - History of mental illness; - Suicide risk; - Family history of mental illness; - DSM-III-R diagnosis; - Treatment recommendations | Alcohol; - Setting; - Inpatient; - Under medical supervision; - Follow admission procedures; - [image] Monitor for S/S of AWS; - [image] Antabuse: contraindicated; - Inpatient AOD treatment whenever possible; - Outpatient AOD treatment with special focus on prognancy issues and drug use; - Encourage and monitor continued prenatal care | Cocaine; - Setting; - Inpatient most effective; - Follow admission procedures; - [image] Medication contraindicated, except in cases of extreme agitation; - Inpatient AOD treatment whenever possible; - Outpatient AOD treatment if necessary, with special focus on pregnancy issues and drug use; - Encourage and monitor continued prenatal care | Opiates; - Setting; - Outpatient or inpatient; - Follow admission procedures; - Methadone maintenance recommended with psychosocial counseling; - Medical withdrawal not recommended; - Encourage and monitor continued prenatal care | Methadone; - Medical withdrawal from methadone not recommended; - Encourage and monitor continued prenatal care | Sedative-Hypnotics; - Setting; - Inpatient; - Under medical supervision; - Follow admission procedures; - [image] Monitor for severe symptoms: seizures, delirium; - [image] Determine risk/benefit ratio when considering use of medications; - Encourage and monitor continued prenatal care | - [underlined: Case Management and Followup]; Case Management; - Individual, group, and family counseling; - Support groups; - Educational program; - Urine and/or blood toxicologies; Social Services; - Financial; - Housing; - Transportation; - Child care/support; - Abuse: physical, mental, sexual; - Parenting; - Education; - Employment; - Legal; - Home management; Ethical/Legal Issues; - Confidentiality; - Reporting; - Child protective services; - Court Involvement; - Informed consent

LEGEND

[image] Medical Caution

AOD: Alcohol and Other Drugs

Substance-Using: Women at risk for problems resulting from their use/abuse of alcohol and other drugs

Point of Entry: Prenatal Care

Patients | Prenatal Intake [image] | Prenatal Followup [image] | Labor/Delivery with Prenatal Care [image] | Labor/Delivery with No Prenatal Care [image] | Postpartum [image] | Neonatal [image] | Nutrition [image] | Refer for Alcohol and Other Drug Treatment
All Pregnant, Substance-Using Women | - Complete detailed health history; - Perform physical exam; - Complete family history; - Complete health history of baby's father, if possible; - Complete routine prenatal panel; - Complete other tests, including tuberculin test with antigen panel, urine toxicology/blood screening, and baseline sonogram; - Optional tests as needed; - [image] Check for tracks, abscesses, poor general hygiene, poor dental hygiene, infections; - Refer for AOD treatment, social services, nutrition counseling, parenting education, employment counseling, others as needed; - Review sexual practices and provide education on safer sexual practices; - Obtain written release | - Identify medical and psychosocial problems; - Provide health education opportunities; - Obtain random urine and/or blood toxicologies; - Reinforce importance of AOD treatment; - Discuss reproductive options; - Manage common complications; - Encourage involvement of father of baby or significant other | - Complete detailed health history; - Perform physical exam; - Query for recent AOD use; - Repeat hepatitis B and HIV screens and syphilis test, if previously negative; - Complete urine and/or blood toxicologies; - [image] Follow universal precautions and OSHA standards; - [image] Notify pediatric, nursing, and social services; - Monitor fetus; - Provide pain management; - Select delivery method; - Insert central line if needed | - Follow all guidelines in previous column, if possible, plus perform:; - Sonogram; - Complete baseline laboratory tests | - Encourage continued participation in AOD treatment; - Encourage and educate about family planning; - Permit breastfeeding in methadone-maintained mothers; - Initiate preventive health maintenance program; - Provide for child care and parenting education; - Conduct postpartum followup | - Obtain urine and/or blood toxicologies; - Monitor for effects of drugs on the infant; - Treat appropriately, depending on drug; - Review case with mother and educate her regarding special care of infant; - Encourage involvement of father of baby or significant other, and family members | - Provide for nutrition assessment; - Develop special care plans according to specific effects of each drug; - Alcohol; - Cigarettes; - Marijuana; - Heroin; - Cocaine; - Other; - Provide for:; - Prevention and intervention; - Nutrition counseling; - Multivitamin and mineral supplements; - Special concerns | [image]; - [underlined: Case Management and Followup]; Case Management; - Individual, group, and family counseling; - Support groups; - Educational program; - Urine and/or blood toxicologies; Social Services; - Financial; - Housing; - Transportation; - Child care/support; - Abuse: physical, mental, sexual; - Parenting; - Education; - Employment; - Legal; - Home management; Ethical/Legal Issues; - Confidentiality; - Reporting; - Child protective services; - Court Involvement; - Informed consent
[image] Additions for HIV-Positive Women | - Refer for specific HIV medical treatment; - Conduct extensive review of symptoms; - Obtain T4 or CD4 count | - Reinforce importance of HIV medical treatment; - Repeat CD4 count every trimester; - Ensure special pediatric followup | - Provide special handling of cord, placenta, and neonate | - Follow guidelines in previous column | - Conduct postpartum followup; - Breastfeeding contraindicated; - Encourage continued participation with HIV specialist for medical followup for mother and infant; - Educate mother regarding special needs of infant; - Encourage and educate about family planning | - Ensure special pediatric followup

LEGEND

[image] Medical Caution

AOD: Alcohol and Other Drugs

Substance-Using: Women at risk for problems resulting from their use/abuse of alcohol and other drugs