# Appendix H—Contributors

These treatment improvement guidelines for pregnant, substance-using women were prepared using protocols and other materials that were developed by a broad range of programs from across the Nation. Many of these programs currently receive grant funds through the Center for Substance Abuse Prevention (formerly the Office for Substance Abuse Prevention [OSAP]). The Consensus Panel gratefully acknowledges the assistance of CSAP in providing access to these grantee materials. The Panel is also grateful to the many professionals in the alcohol and drug treatment field who so generously provided access to their program materials. These contributing programs are listed below.

The suggestions and comments of expert field reviewers were particularly helpful in enhancing the quality of the final guidelines. These individuals were selected to review and comment on the draft document based on their knowledge of and concern for the special needs of pregnant, substance-using women. The Consensus Panel appreciates and acknowledges the time and substantive quality of their comments. These individuals are also listed below.

## Programs Contributing To the TIP

- Addiction Research Foundation
- Toronto, Ontario, Canada

- Alameda County Health Care Services Agency
- Highland General Hospital Healthy Infant Program

- Oakland, California
- Baltimore City Health Department

- Baltimore Project
- Baltimore, Maryland

- Beth Israel Hospital
- New York, New York

- Born Free Project
- Dayton, Ohio

- Boston Hospital
- Boston, Massachusetts

- Brandywine Counseling, Inc.
- Small Wonders Project
- Wilmington, Delaware

- California Health Services Department
- Sacramento, California

- CASPAR, Inc.
- Intervention Center
- Somerville, Massachusetts

- Center Point Lifestart Program
- San Rafael, California

- Charles R. Drew University
- Los Angeles, California

- Connecticut Department of Health Services
- Community Health
- Hartford, Connecticut

- Contra Costa County Department of Health Services
- Martinez, California

- Deaconess Medical Center
- Chemical Dependency Units

- Spokane, Washington
- Dimock Community Health Center

- Roxbury, Massachusetts
- Division of Public Health Services

- Bureau of Maternal and Child Health
- Concord, New Hampshire

- Eden Center
- Compton, California

- Emory University
- Atlanta, Georgia

- Faulkner Hospital
- Jamaica Plain, Massachusetts

- Fenway Community Health Center
- Boston, Massachusetts

- Florida Department of Health and Rehabilitation Services
- Pensacola, Florida

- Framingham Union Hospital
- SYNTHESIS
- Framingham, Massachusetts

- Genesis Family Day Treatment Program
- Los Angeles, California

- Georgia Addiction, Pregnancy and Parenting Program
- Atlanta, Georgia

- Harlem Hospital Center
- Department of Obstetrics and Gynecology
- New York, New York

- Health Crisis Network
- Miami, Florida

- Health Federation of Philadelphia
- Philadelphia, Pennsylvania

- Heritage Hospital
- Women's Addiction Program
- Somerville, Massachusetts

- Illinois Department of Public Health
- Perinatal Addiction Program
- Springfield, Illinois

- Johns Hopkins Comprehensive Women's Center

- Baltimore, Maryland

- Lake County Health Department
- Waukegan, Illinois

- Lincoln Hospital Maternal Substance Abuse Services
- Bronx, New York

- Los Angeles County Inter-Agency Council on Child Abuse and Neglect
- Los Angeles, California

- Medical and Health Research Association of New York City (MIC-FPPMHRA)
- Maternity Infant Care -- Family Planning Projects
- New York, New York

- Medical College of Pennsylvania
- Philadelphia, Pennsylvania

- Meharry Medical College
- Department of Obstetrics and Gynecology
- Nashville, Tennessee

- Memorial Hospital Department of Family Medicine
- Blackstone Valley Perinatal Network
- Pawtucket, Rhode Island

- Mendocino County Department of Public Health
- Ukiah, California

- Miami Valley Hospital
- Dayton, Ohio

- Michigan Department of Corrections Project
- Transition/League of Catholic Women
- Detroit, Michigan

- Monterey County Department of Health
- Salinas, California

- Mount Zion Hospital and Medical Center
- San Francisco, California

- National Association for Perinatal Addiction Research and Education
- Chicago, Illinois

- New York City Department of Health
- New York, New York

- New York State Department of Health
- Albany, New York

- Oklahoma State Department of Health
- Oklahoma City, Oklahoma

- Operation PAR
- St. Petersburg, Florida

- Parent-Child Intervention Program
- East Palo Alto, California

- Presbyterian Hospital
- New York, New York

- Project WIN
- Brighton, Massachusetts

- Providence Hospital Perinatal Program
- Holyoke, Massachusetts

- Puget Sound Hospital
- Tacoma, Washington

- Sacred Heart Medical Center Foundation
- New Start: Drug Free Beginnings for Moms and Babies
- Eugene, Oregon

- San Francisco Department of Public Health
- San Francisco, California

- San Mateo County Department of Health Services
- San Mateo, California

- Santa Clara County Health Department
- Campbell, California

- Santa Clara County
- Perinatal Substance Abuse Treatment Program
- San Jose, California

- Shands Hospital
- Gainesville, Florida

- Snohomish Health District Community Health Division Snohomish County, Washington
- Special Intervention Team Project
- Snohomish County, Washington

- Spectrum Addiction Services, Inc.
- Worcester, Massachusetts

- Spokane County Health District Family Success Program
- Spokane, Washington

- St. Francis Medical Center
- National Addiction Project
- Pittsburgh, Pennsylvania

- St. Vincent's Medical Center
- Hope for Families
- Toledo, Ohio

- Stanley Street Treatment and Resources, Inc.
- Fall River, Massachusetts

- State of Oregon Department of Human Resources
- Children's Service Division Salem, Oregon

- Tarzana Treatment Center
- Tarzana, California

- Thomas Jefferson University Hospital Family Center Program
- Philadelphia, Pennsylvania

- Toronto Hospital
- Toronto, Ontario, Canada

- UCLA Department of Pediatrics
- Statewide Outreach Training Project
- Los Angeles, California

- University of Florida
- College of Medicine Prenatal and Interconceptional Support of Substance-Abusing Moms Maternity and Infant Care Project
- Gainesville, Florida

- University of Washington Medical Center
- Seattle, Washington

- Washington County Department of Health and Human Services
- Project Cradle
- Hillsboro, Oregon

- Washington State Department of Social and Health
- Services Division of Alcohol and Substance Abuse
- Olympia, Washington

- Women's Intervention Services and Education
- Pensacola, Florida

## TIP Field Reviewers

- Barbara Bennett, M.D.
- Co-Chair, American Society for Addiction Medicine
- Perinatal Addiction Committee
- Corte Madera, California

- Haywood L. Brown, M.D.
- Associate Professor
- Department of Obstetrics-Gynecology
- Project Director Comprehensive Maternal/Child Health Project
- Wishard Memorial Hospital
- Indianapolis, Indiana

- Barbara A. Brustman, Ed.D
- Research Director
- Perinatal Health Unit Division of Family Health
- Center for Community Health
- New York State Department of Health
- Albany, New York

- Judith C. Burnison
- Executive Director
- National Association for Perinatal Addiction Research and Education
- Chicago, Illinois

- Jane B. Chappell, R.N., M.S.N.
- Director
- Tri-Cap Family Health Services
- Dubois-Pike-Warrick Economic Opportunity Committee, Inc.
- Jasper, Indiana

- Garrett H.C. Colmorgen, M.D.
- Director, Maternal-Fetal Medicine T
- he Medical Center of Delaware
- Newark, Delaware

- Sheri L. Cooper
- Substance Exposed Infants Coordinator
- Senior Human Services Program Specialist
- State of Florida
- Department of Health and Rehabilitative Services
- Alcohol, Drug Abuse and Mental Health
- Tallahassee, Florida

- Ann DeClue, M.D.
- Medical Director
- Columbus Hospital Women's Chemical Dependence Program
- Chicago, Illinois

- Mianne Edwards
- Program Manager
- New Jersey Department of Health
- Division of Alcoholism, Drug Abuse and Addiction Services
- Trenton, New Jersey

- Bery Engebretson, M.D.
- Executive Director
- Primary Health Care, Inc.
- Des Moines, Iowa

- Norma Finkelstein, Ph.D.
- Director
- Coalition on Addiction, Pregnancy, and Parenting
- Cambridge, Massachusetts

- Richard K. Fuller, M.D.
- Director, Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, Maryland

- Preston M. Gazaway, M.D.
- Director of Obstetrics Center for Addiction in Pregnancy
- Francis Scott Key Medical Center
- Baltimore, Maryland

- Kristine M. Gebbie, R.N., M.N., F.A.A.N.
- Secretary of Health
- Washington State Department of Health
- Olympia, Washington

- Catherine Gorham, C.S.W.
- Project Development Specialist
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas

- Louise Haynes, M.S.W.
- Director, Office of Women's Services
- South Carolina Commission on Alcohol and Drug Abuse
- Columbia, South Carolina

- DeLoris L-James Hunter, Ph.D.
- Executive Assistant to the Director
- Center for Substance Abuse Prevention
- Rockville, Maryland

- Ronald W. Kemp
- Executive Director
- Peoples Community Health Clinic, Inc.
- Waterloo, Iowa

- Lorraine V. Klerman, Dr. P.H.
- Professor of Public Health
- Department of Epidemiology and Public Health
- School of Medicine
- Yale University
- New Haven, Connecticut

- Mary Ann LaFazia
- State of Washington
- Department of Social and Health Services
- Olympia, Washington

- Robert A. MacLean, M.D.
- Acting Commissioner of Health
- Texas Department of Health
- Austin, Texas

- Karen Madry, Ph.D.
- Research Specialist
- Texas Commission on Alcohol and Drug Abuse
- Austin, Texas

- Kay Malone, R.N., C.D., M.H.S.
- Nursing Supervisor
- Projects Director
- Brandywine Counseling, Inc.
- Newark, Delaware

- Jan L. Morris, M.Ed., N.C.C.
- Training Administrator
- Delaware Division of Alcoholism, Drug Abuse, and Mental Health
- New Castle, Delaware

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates, Inc.
- San Antonio, Texas

- Suzanne W. Perry
- Regional Program Coordinator
- Division of Alcoholism and Drug Abuse
- Alaska Department of Health and Social Services
- Juneau, Alaska

- Nancy A. Pyle, R.N.C., M.S.N., C.P.N.P.
- Coordinator Allen County, Indiana Prenatal Substance Abuse Prevention Program
- Three Rivers Health Services, Inc.
- Fort Wayne, Indiana

- Patricia A. Redmond
- Deputy Division Director for Substance Abuse Services
- Georgia Substance Abuse Services
- Division of Mental Health, Mental Retardation and Substance Abuse
- Atlanta, Georgia

- Diane E. Rogers, Ph.D.
- Director
- Amethyst Counseling Services
- Eugene, Oregon

- Carol A. Sauers, M.S.S.W.
- Women's Program Administrator
- Division of Substance Abuse
- Kentucky Department for Mental Health and Mental Retardation
- Frankfort, Kentucky

- Lois A. Schipper, R.N., M.P.H.
- Nurse Consultant
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- Department of Health and Human Services
- Rockville, Maryland

- Manuel Schydlower, M.D.
- Chairman, Committee on Substance Abuse
- American Academy of Pediatrics
- Elk Grove Village, Illinois

- Kenneth D. Stark
- Director
- Division of Alcohol and Substance Abuse
- Washington Department of Social and Health Services
- Olympia, Washington

- Carolyn Suchecki, B.S., R.N.
- Quality Assurance Coordinator
- Connecticut Alcohol and Drug Abuse Commission
- Hartford, Connecticut

- Maria Vandor
- Director of Women and Children's Services
- New York State Division of Substance Abuse Services
- New York, New York

- Lor Wiener, Ph.D.
- Coordinator
- Pediatric HIV Psychosocial Support Program
- Pediatric Branch
- National Cancer Institute
- Bethesda, Maryland

- Lester Wright, M.D., M.P.H.
- Chairman
- Department of Health Administration
- School of Public Health
- Loma Linda University
- Loma Linda, California