# Appendix E—Glossary of Terms

abruptio placentae: : premature detachment of a normally situated placenta.

adjudicate: : to pronounce or decree by judicial sentence.

AIDS: : acquired immunodeficiency syndrome. A disease characterized by opportunistic infections (e.g., Pneumocystis carinii pneumonia, candidiasis, Kaposi's sarcoma) in immunocompromised persons; caused by the human immunodeficiency virus (HIV) and transmitted by exchange of body fluids.

amniocentesis: : a procedure whereby fluid is aspirated from the amniotic sac through the abdomen.

anergy: : absence of demonstrable sensitivity reaction in a subject to substances that would be antigenic (immunogenic, allergenic) in most other subjects. Anergia; lack of energy.

anomaly: : deviation from the average or norm; anything structurally unusual or irregular or contrary to a general rule.

anorexia: : diminished appetite, aversion to food.

asymptomatic: : without signs or symptoms.

bacteremia: : the presence of viable bacteria in the circulating blood.

booting: : any drug solution, such as cocaine or heroin, mixed with blood aspirated into a syringe and then injected into a vein, repeated one or more times to clear the syringe barrel and tip of any of the drug residue. Heavy blood contamination of the syringe may contribute to colonization with bacterial pathogens and to the more likely transmission of the human immunodeficiency virus (HIV).

case manager: : one who defines, initiates, and monitors the medical, drug treatment, psychosocial, and social services provided for the woman and her family.

cervical dysplasia: : abnormal tissue development of the uterine cervix.

chancroid: : an acute bacterial infection characterized by single or multiple ulcers or sores in the genital area; an infectious venereal ulcer with a soft base.

chlamydia: : a sexually transmitted disease manifested by mucopurulent endocervical discharge and inflammation of the endocervical columnar epithelium. Symptoms may be moderate or scanty discharge, urethral itching, and burning on urination, but patients are often asymptomatic.

condylomata: : a wart-like excrescence at the anus, vulva, or on the glans penis caused by the human papilloma virus (HPV).

congenital: : existing at birth. Refers to certain mental or physical traits, anomalies, malformations, or diseases which may be either hereditary or due to an influence occurring during gestation up to the moment of birth.

cross training: : to be trained in several disciplines to facilitate broader coverage in a treatment unit.

dysuria: : difficulty or pain in urination.

diaphoresis: : increased perspiration.

dyspnea: : shortness of breath.

embryo: : the developing organism from conception until approximately the end of the second month.

endocarditis: : inflammation of the lining of the heart.

epidemiology: : the study of the relationship between various factors that determine the frequency and distribution of diseases in human and other animal populations.

fetus: : the unborn young from the end of the eighth week to the moment of birth.

folliculitis: : an inflammation of the hair follicles. The lesions may be papules (small skin elevations) or pustules.

fungal infections: : a general term used to describe those diseases caused by diverse morphological forms of yeasts and molds.

genitourinary: : pertaining to the organs of reproduction and urination.

gestation: : the process, state, or period of pregnancy.

gonorrhea: : a sexually transmitted disease manifested by an inflammation of the genital mucus membrane.

hairy leukoplakia: : a white lesion appearing on the tongue of patients with AIDS. The lesion appears raised, with a corrugated or "hairy" surface, due to keratin projections (a substance found in the dead outer corneal skin layer and in hair and nails).

hemangiomas: : a congenital anomaly in which a proliferation of vascular endothelium leads to a mass that resembles neoplastic tissue. It can occur anywhere in the body, but is most frequently noticed in the skin and subcutaneous tissue.

hepatitis: : inflammation of the liver, usually from a viral infection, but sometimes from toxic agents.

hepatomegaly: : enlargement of the liver.

herpes simplex: : a virus that in humans causes fever blisters, usually on the lips and external nares (nose), and also on the genitalia. This virus may also cause acute stomatitis and meningoencephalitis.

histoplasmosis: : Darling's disease. An infectious disease manifested by a primary benign pneumonitis similar to primary tuberculosis.

HIV: : human immunodeficiency virus. The virus occurring in humans that causes a condition that results in a defective immunological mechanism, opportunistic infections, and eventually in the disease process know as AIDS (acquired immunodeficiency syndrome).

hyperpnea: : breathing that is deeper and more rapid than is normal at rest.

hyperpyrexia: : an abnormally high fever.

hypotonia: : having a lesser degree of tension in any part of the body.

icterus: : relating to or marked by jaundice.

infant: : a child under the age of 1 year.

Kaposi's sarcoma (K.S.): : malignant neoplasm occurring in the skin and sometimes in lymph nodes, manifested by cutaneous lesions consisting of reddish-purple to dark blue macules, plaques, or nodules. It is seen mostly in men and as an opportunistic disease in AIDS patients.

ketoacidosis: : enhanced production of ketone bodies due to alcohol or diabetes.

lymphadenopathy: : any disease process affecting a lymph node or nodes; clinically refers to enlargement of nodes.

meconium: : the first intestinal discharge of the newborn infant.

microcephaly: : pertaining to abnormal smallness of the head.

morbidity: : pertaining to severe illness.

mortality: : pertaining to death.

mucopurulent: : containing or composed of mucus and pus.

myoclonic: : spasm or twitching of a muscle.

neonate: : a newborn. Refers to the period immediately following birth and continuing through the first 28 days of life.

neurotropic: : a virus or drug that has an affinity for nerve cells or tissue.

nosocomial: : denotes a new disorder not related to patient's original condition that is associated with being treated in a hospital, e.g., a hospital-acquired infection.

ocular: : pertaining to the eyes.

odynophagia: : pain on swallowing.

paresthesia: : an abnormal sensation, such as burning, pricking, tickling, and tingling.

perinatal: : occurring during, or pertaining to, the periods before, during, or after the time of birth, i.e., from the 28th week of gestation through the first seven days after delivery.

postnatal: : occurring after birth.

prenatal: : occurring before birth.

prophylaxis: : to guard against or take precautions that will prevent either disease or a process that can lead to disease.

pruritus: : itching.

psychotropic: : pertaining to drugs used in the treatment of mental illness; affecting the mind.

pyoderma: : skin infection characterized by the formation of pus.

retinitis: : inflammation of the retina, which may be caused by the cytomegalovirus (CMV).

seborrheic dermatitis: : overactivity of the sebaceous glands resulting in a scaly macular eruption that occurs primarily on the face, scalp (dandruff), and pubic and anal areas.

septicemia: : systemic disease caused by the spread of microorganisms and their toxins via the bloodstream.

sonogram: : an image obtained by ultrasound, used to produce an image of the fetus.

splenomegaly: : enlargement of the spleen.

spontaneous abortion: : the loss of an embryo or fetus prior to the stage of viability at about 20 weeks of gestation as a result of natural causes (not artificially induced).

stabilization: : the accomplishment of a steady, nonvarying physical state.

sudden infant death syndrome (SIDS): : the unexpected death of an apparently healthy baby, usually occurring during sleep, without apparent cause.

syndrome: : the combination of signs and symptoms associated with any morbid process, which together constitute the picture of the disease.

syphilis: : an acute and chronic infectious, sexually transmitted disease. Syphilis is manifested first by a chancre, followed by a slight fever, and progresses through several stages that include skin eruptions and functional abnormalities resulting from cardiovascular and nervous system lesions.

tachypnea: : rapid breathing.

tenesmus: : the urgent feeling of a need to urinate or defecate without the ability to do so.

teratogen: : a drug or other agent that causes abnormal fetal development.

thrombocytosis: : an increase in the number of platelets in the circulating blood.

toxemia: : a metabolic disorder of pregnancy characterized by hypertension, edema, and albumin in the urine. Also known as pregnancy-induced hypertension (PIH) or pre-eclampsia.

toxoplasmosis: : disease caused by protozoan parasite. This prenatally acquired human infection from cat litter boxes can result in an infant with micro- cephalus or hydrocephalus at birth as well as other abnormalities.

thrush: : infection of the oral (mouth) tissues with Candida albicans.

urine toxicology: : the science dealing with the detection of drugs in the urine.

vaginal candidiasis: : infection in the vagina manifested by yeast-like fungi.