# Appendix D—Quality Assurance Monitoring

Alcohol and other drug treatment programs have increasingly used quality assurance (QA) techniques to maintain or improve the level of care provided to patients and to contain costs. In addition, a quality assurance component is often mandated for the licensure and reimbursement of treatment programs. Every treatment program should have an ongoing and active quality assurance program.

Experience has demonstrated that pregnant, substance-abusing women entering treatment need a wide range of support services. To provide this comprehensive level of care, treatment staff must marshall the resources of a host of other agencies through referral and collaboration. The careful monitoring of these referral and interagency collaborative activities on behalf of patients is a key quality assurance function for treatment programs. Monitoring should cover these aspects:

- Documentation of referrals and the sharing of patient information
- Compliance with Federal and State confidentiality regulations
- Preparation of interagency agreements
- Assurance of linkage and documentation of collaborative activities

## Referrals and Information Sharing

It is well known that merely making referrals for patients neither ensures that services are received nor guarantees the quality of the services that are delivered. One of the key functions of a QA program is to monitor the process of referral. A well-designed QA program will routinely select a sample of all patient records and related referrals and monitor these sources to ensure that linkage has occurred.

Documentation must be made of the results of the monitoring and related actions taken to correct any problems and improve services. Examples of quality assurance monitoring activities are as follows:

- Monitor patient records to ensure that proper referrals were made.
- Monitor patient records to ensure that appropriate and necessary information was shared with the referral agency (e.g., reason for the referral and problems to be addressed).
- Monitor referral logs, payment vouchers, or other referral documentation for completeness and appropriateness (e.g., Is payment appropriate to the services provided?).
- Monitor patient records to ensure that linkage was documented (e.g., Was the patient evaluated and accepted for services?).
- Monitor patient records for notes of treatment progress and/or continued service (e.g., regular documentation of treatment progress), or documentation that services were no longer needed (e.g., documentation of the followup services that were being provided and why services were no longer needed).

## Confidentiality Compliance

Every agency that provides services to pregnant, substance-using women must ensure that internal policies and procedures comply with both Federal and State confidentiality and reporting regulations (see Guideline 17 -- Confidentiality and Reporting). Once compliance is ensured through the development of policies and staff training, a process of quality assurance monitoring should be developed to routinely review a sample of all program records. Documentation must be made of the results of such monitoring and related actions taken to correct any problems and improve services. Examples of quality assurance monitoring activities are as follows:

- Monitor for documentation that service providers informed patients of their rights to confidentiality and offered information about possible court involvement.
- Monitor for documentation that service providers informed patients of all laws that were relevant to their specific circumstances.
- Monitor to ensure that there is a written informed consent on file whenever there were discussions concerning patients with individuals or organizations outside the treatment facility.
- Monitor to ensure that the written informed consent is time-limited, content-specific, person-to-person, signed, and witnessed.

## Interagency Agreements

In order for interagency collaboration and linkage to be successful, there must be a written document that clearly delineates the responsibilities of the cooperating agencies. Interagency agreements, at a minimum, should have these characteristics:

- Describe the services to be provided by each agency.
- Describe the referral process to be used and the documentation requirements of each agency.
- Establish a timeframe for the review and possible revision of the agreement.

Examples of quality assurance monitoring activities are as follows:

- Monitor to ensure that the referring agency provided all appropriate and necessary patient information to the referral agency.
- Monitor to ensure that there is documentation that the referral agency provided all agreed-upon services in a timely manner.
- Monitor to ensure that the referral agency provided documentation to the referring agency of patient progress, continued need for services, or readiness for termination of services.

## Other Important Areas for Quality Assurance Monitoring

Additional aspects of linkage and collaborative activity that are appropriate for quality assurance monitoring include:

- Monitor to ensure that linkage occurred, as demonstrated by the acceptance of patients into followup care.
- Monitor to ensure that there is documentation for patients who were not accepted for treatment (e.g., reasons why patients were not appropriate for the facility, and what steps were taken to link patients to appropriate services).
- Monitor to ensure that there is documentation for the discharge of pregnant patients. Although the discharge of pregnant patients from treatment is not recommended, occasions may arise that necessitate this course of action. There must be full documentation of the rationale for discharge and the attempts that were made to maintain patients in treatment. For example, when patients are discharged for noncompliance, there must be documentation of the steps taken to encourage treatment compliance. Similarly, there should be documentation of the referral of patients to alternative treatment.
- Monitor to ensure that there is documentation of the referral of patients when the agency was unable to provide necessary services (e.g., Are patients referred to a methadone program when needed?).

Monitor to ensure that patients have a treatment plan listing all required services and that there is documentation of patient progress for all referred services.