# Appendix C—Continuum of Care Model Program

This section presents a model program and sample budget for State agency and local treatment staff to use in providing services for pregnant, substance-using women. The section identifies specific services, presents staffing patterns, and includes costing assumptions recommended by experts from the fields of alcohol and other drug treatment and mental health.

A model program has been designed with the understanding that not all States or localities are able to begin new programs. This model program is intended to be used as a guide or standard for developing a program, adding new services, or incorporating some of the guidelines into an already-existing program.

The sample budget is based on the model program and lays out the requirements and formulas for estimating program costs. The cost assumptions can be tailored to conditions that prevail in different geographic areas. For example, to estimate labor costs in a specific location, the prevailing salary/wage rates should be substituted for the rates used here.

A list of Medicaid reimbursement rates for various medical procedures is presented as a guide. These rates represent the average reimbursement rate paid to States. A program's actual reimbursement rate for individual procedures may vary. Additional help on how to tailor the cost model is provided later in this section.

## Continuum of Care Model Program

The model program is specifically designed to meet the special needs of pregnant, substance-using women. The goal of the program is to provide comprehensive services that are appropriate and sensitive to the needs of the target population -- services that will enable women to secure prenatal care and other support throughout pregnancy, to achieve a successful delivery, and to receive 3 months of postpartum care.

Services will be provided by a multidisciplinary team of health professionals, including medical or psychiatric social workers, obstetrical/gynecological (Ob/Gyn) specialists, clinical nurse practitioners, and outreach workers. All health care services will be provided in one setting, with the exception of laboratory work. If the patient needs to undergo medical withdrawal or be hospitalized, referrals will be made to the appropriate programs.

The model program will provide outreach services, laboratory workups, obstetrical and gynecological physicals, social work intervention, and appropriate followup services. In addition, the program will provide diagnosis, evaluation, and short-term clinical interventions, along with medical management, to avoid exacerbation of symptoms and unnecessary hospitalizations.

A case management model is used and will be directed by the medical or psychiatric social worker to ensure that concrete services, advocacy, referral, and linkages to other service providers in the community are available. The woman's transition into providing child care and parenting will be facilitated by a complete and thorough assessment of her needs and the development of a comprehensive treatment plan.

### Continuum of Care Process and Staffing Pattern

The staffing pattern for the model program is designed around a rotating team concept. There will be four treatment teams consisting of an outreach worker, medical or psychiatric social worker, Ob/Gyn physician, and clinical nurse practitioner. Each treatment team will have a caseload of no more than 20 women, and the overall program capacity will be 80 slots. Initial staffing, outreach, intake, and patient scheduling will vary, and it may take several months for the program to be fully operational.

During the first few months of program startup, the four outreach workers will be on-call each week. Based on their experience and knowledge of the treatment field, the workers will provide outreach to women who are suspected alcohol and other drug abusers. They will engage the women and facilitate their entry into the program for prenatal care, delivery, and followup.

The four clinical nurse practitioners will function as the intake team. Their duties will include facilitating all necessary workups prior to the first prenatal visit and physical examination by the physician. All laboratory tests will be completed and results given to the physician for review within 1 month.

Unless there is a medical emergency, an appointment with the physician will be scheduled for the patient within the first 2 months of the first trimester. The physician will see the patient on a monthly basis during the second trimester and weekly visits will be scheduled during the third trimester. It is anticipated that two part-time Ob/Gyn specialists should be able to handle the expected caseload.

The four medical or psychiatric social workers will serve as case managers. They will initiate case management services toward the end of the first trimester -- after the patient has undergone preliminary assessment. Each case manager will be responsible for ensuring the patient has access to services within the program and in the community, and will serve as a liaison between the patient and her treatment team. The case manager will work with the patient to ensure that she understands her treatment, including all pertinent medical procedures, laboratory tests, preparation for childbirth, and followup plans.

Additionally, the case manager will provide supportive counseling as needed, facilitate communication between all members of the treatment team, and conduct case conferences among all those involved in the woman's care, including community- based programs or services.

Clinical nurse practitioners will help train the mother in such key areas as child care, parenting, and nutrition. After delivery, the medical or psychiatric social worker will work with the clinical nurse practitioner to facilitate the appropriate integration of the woman and her child into the community.

### Sample Model Program Budget and Costing Overview

The following section looks at the costs associated with the operation of the model program to provide comprehensive medical care and case management services for pregnant, substance-using women that is described above.

The sample budget is based on a static patient population of 80 slots per year. The total number of patients served by the model program will be greater than the number of slots allocated, since patients will enter and leave at different points in the treatment continuum.

The model program budget is based on these assumptions:

- The average length of stay in the model program is 1 year.
- The model program is fully operational.
- A range of salaries is presented, although the total budget reflects the high end of the range. Actual salaries will vary by geographic area.
- Two half-time physicians are hired for a total of one full-time equivalent (FTE) position.
- Laboratory charges are based on a limited national survey and on single-unit prices. Actual costs will vary by geographic area, particularly if volume- discounts are available. Costs for sonograms are not included.
- An administrative overhead charge of 20 percent of total wages and fringe benefits is included in the model budget to provide for the costs of administrative supervision and support.
- The fringe benefit rate is calculated at 30 percent.
- A transportation allowance of $20 per patient slot is included in the budget to cover the cost of bus tokens, cab vouchers, and so forth.
- The budget does not include indirect costs necessary for the operation of a facility. Examples of indirect costs that should be considered part of an operating budget include
  - space rental
  - utilities
  - telephone
  - cleaning
  - insurance
  - equipment purchase/rental and maintenance/repairs
  - office supplies
  - depreciation
  - security services

### Other Cost Implications

The sample budget does not include costs for delivery of the baby or for alcohol and other drug treatment, including medical withdrawal. These costs would be incurred regardless of the new services a program might offer, and vary from State to State.

The program budget also does not look at reimbursement issues. Before deciding to implement this program, Federal, State, local, and third party reimbursement programs need to be studied. These reimbursement sources may pay for part or all of any new services suggested by this model.

### Summary

The need for comprehensive services for pregnant, substance-using women is clear. The model program offers a case management approach to address the total needs of this population. Given the complexities of treating pregnant, substance-using women and the relative lack of resources, a significant number of women do not receive adequate care. The information provided in the guidelines, along with the suggestions in this section for program design, staffing, and costing, are intended to guide States and local treat- ment programs in their efforts to provide services to this population.

Sample Program Budget

Pregnant, Substance-Using Women Sample Program Budget Program Capacity for 80 Treatment Slots
Personnel Costs
Position | Full Time equivalents needed | Salary Range Per Year | Estimated Cost*
Program Director | 1 | $45,000-65,000 | $65,000
Nurse Practitioner | 4 | $30,000-40,000 | $160,000
Physician (Ob/Gyn) | 1 | $100,000-120,000 | $120,000
Psychiatric/Medical Social Worker | 4 | $30,00-45,000 | $180,000
Outreach Worker | 4 | $20,00-30,000 | $120,000
Total Wages | | | $645,000
Fringe Benefits @ 30% of wages | | | $193,500
Total Personnel Costs | | | $838,500
Other Costs | | | Cost
Laboratory (80 patients @ $783.42) | | | $62,674
Clinical Supplies (80 patients @ $40) | | | $3,200
Publications | | | $1,000
Training and Conferences ($250/staff member) | | | $3,500
Transportation ($20/patient) | | | 1,600
Administrative Overhead @ 20% of wages and fringes | | | $167,700
Total Other Cost | | | $239,674
Total Personnel and Other Costs | | | $1,078,174
*Estimated personnel costs were calculated using the high end of the salary range. These costs will vary widely by State and locale.

Medicaid Reimbursement Rates for Medical Procedures*

Medicaid Reimbursement Rates for Medical Procedures
Physicians' Current Procedural Terminology code | Name of Procedure | Average Medicaid payment
I. Routine Prenatal Workup -- Initial
80009 | Liver profile | $11.08
80019 | Chem screen 30(A generic for more than 19 tests and coded the same as Chem 20) | 15.04
82055 | Blood alcohol | 15.56
82150 | Amalyse | 8.57
82660 | Urine drug screen panel | 14.49
82952 | Glucose challenge | 7.01
83053 | Sickle cell | 6.93
83690 | Lipase | 8.22
83705 | Lipids, fractionated; cholesterol, triglycerides, and phospholipids | 15.28
84450 | AST | 5.91
85024 | CBC -- Complete Blood Count | 10.98
86016 | Antibody screen | 8.89
86082 | ABO type and Rh factor | 6.72
86255 | Fluorescent antibody; screen each antibody (e.g., chlamydia, toxoplasmosis, and herpes screening) | 12.81 (price per antibody screen)
86287 | Hepatitis B surface antigen screen | 13.89
86299 | Hepatitis A (IgM Anti-HAV)(HAA) | 14.92
86312 | HIV-EIA | 13.06
86403 | Particle agglutination rapid test (e.g., rubella antibody; cryptoccocal antigen) | 13.77
86580 | Tuberculosis, intradermal (Mantoux) | 6.49
86592 | RPR-syphilis (qualitative) | 4.70
87070 | Neisseria gonorrhea culture | 11.93
87205 | Smear, primary source, with interpretation; routine stain for bacteria, fungi, or cell types Cervical smear -- gonorrhea, gram stain of exudative material, vaginal culture | 5.43
88150 | Cytophathology, smears, cervical or vaginal (e.g., Papanicolaou smear) up to three smears | 7.18
Subtotal | | $238.86
II. Confirmatory and Followup Tests
83020 | Hgb Electrophresis -- for positive sickle cells Hemoglobin electrophorism | 12.54
86299 | HAA confirmatory test | 14.92
86319 | GC/MS confirmation -- for positive urine drug screens | 23.41
Subtotal | | $50.87
III. Prepartum Periodic Monitoring
80019 | Chem screen 20(repeat every 2 months; coded same as Chem 30) | $45.12 (3 tests @ $15.04)
82660 | Urine drug screen panel (repeat every month) | 101.43 (7 tests @ $14.49)
84450 | AST (repeat every month) | 41.37 (7 tests @ $5.91)
86016 | Antibody screen (repeat every 2 months) | 26.67 (3 tests @ $8.89)
Subtotal | | $214.59
IV. Midterm Pregnancy
86244 | AFP | 18.09
Grand Total | All Tests | $522.41
Source: Special analysis for CSAT done by the Division of Medicaid Statistics, Office of Program Systems, Bureau of Data Management and Strategy, Health Care Financing Administration. Data are from the period July-September 1991. The data were obtained from the individual claims data supplied by State Medicaid agencies to the Medicaid Statistical Information System at the Health Care Financing Administration. The participating States were Alaska, Alabama, California, Delaware, Georgia, Indiana, Iowa, Kansas, Kentucky, Maine, Missouri, Montana, New Jersey, North Dakota, New Hampshire, Utah, Vermont, Washington, Wisconsin, and Wyoming.