# Appendix B—Assessment Instruments

## Introduction

A comprehensive assessment of each patient entering treatment is needed and should include the following:

- History of alcohol and other drug abuse
- Psychosocial history
- Medical history
- Mental health history

A number of assessment instruments are widely used to collect information that is helpful in diagnosis and treatment planning. Examples of some of these instruments are listed below. Other instruments are available that illustrate the ways in which individual treatment programs have developed or tailored assessment tools to meet the particular needs of their patient populations. Examples of some of these latter instruments are also listed.

The listing of a particular assessment instrument in no way implies an endorsement of that instrument, nor is the following list intended to be inclusive or representative of all assessment instruments that may be used by treatment programs. The instruments included here are used or recommended by some treatment providers.

## Ordering Information

A collection of sample assessment instruments is available as a package from the National Clearinghouse for Alcohol and Drug Information (NCADI), P.O. Box 2345, Rockville, MD 20852, 1-800-729-6686. The specific instruments included in the package are identified below as "available from NCADI." Other assessment instruments are available commercially and may be ordered individually from the sources listed.

### Alcohol and Other Drug Use and Psychosocial Assessment Instruments

#### Addiction Severity Index (ASI)

- The ASI is a highly structured clinical interview designed for a trained technician to use to rate the severity of problems in six areas: medical, psychiatric, legal, family and social, employment and support, and use of alcohol and other drugs.
  - Source: McLellan, A.T.; Luborsky, L.; O'Brien, C.P.; and Woody, G.E. An improved evaluation instrument for substance abuse patients: The Addiction Severity Index. Commented out ElementJournal of Nervous and Mental Disease 168:26-33, 1980. Available from NCADI.

#### Addiction Severity Index Pregnancy Status

- This 22-question instrument was developed as an adjunct to the ASI.
  - Source: Maternity, Infant Care-Family Project, Medical and Health Research Association of New York City, Inc., 225 Broadway, New York, NY 10007. Available from NCADI.

#### Assessment/Psychosocial Client Form

- This 20-page self-administered questionnaire covers substance use patterns and treatment, psychological and behavioral issues, legal history, employment, education, activities and peer support, family history, health status, and current or imminent crises.
  - Source: Operation PAR, Inc., 10901-C Roosevelt Boulevard, Suite 1000, St. Petersburg, FL 33716. Available from NCADI.

#### Bio-Psychosocial Assessment

- This 21-page questionnaire covers substance abuse history, biological factors, behavioral factors, early background, culture/spirituality/religion, socio-leisure, sexual history, education, work history, self-identification, and self-image.
  - Source: Brandywine Counseling, Inc., 2400 West Fourth Street, Wilmington, DE 19805. Available from NCADI.

#### CAGE

- The CAGE Questionnaire is a simple, four-item instrument used to detect the addictive nature of drinking.
  - Source: Mayfield, D.G.; McLeod, G; and Hall, P. The CAGE questionnaire: Validation of a new alcoholism screening instrument. Commented out ElementAmerican Journal of Psychiatry 131:1121-1123, 1974.

#### Client Profile

- The Client Profile is a 47-item instrument that covers family history, alcohol and other drug use, health status, education, employment, and legal history.
  - Source: John W. Sherwood, M.A., Dimock Community Health Center, Project Catch the Hope, 55 Dimock Street, Roxbury, MA 02119. Available from NCADI.

#### Drug Interview Questionnaire

- The Drug Interview Questionnaire captures information about all drugs used by a patient, as well as a reproductive history.
  - Source: Georgia Addiction, Pregnancy and Parenting Project, Laboratory of Human and Behavior Genetics, Georgia Mental Health Institute, 1256 Briarcliff Road, N.E., Atlanta, GA 30306. Available from NCADI.

#### Inventory of Drinking Situations (IDS)

- Available in print and software formats, this 100-item questionnaire assesses 8 drinking situations and is intended to be used as a treatment planning tool to help clients avoid high-risk relapse situations.
  - Source: Addiction Research Foundation, 33 Russell Street, Toronto, Canada M5S 2S1, 1-800-661-1111.

#### Maternal Substance Use Survey

- This 22-item survey covers a woman's health status, alcohol and other drug use, and family circumstances. A separate form captures the pattern of drug use prior to and during pregnancy.
  - Source: Operation PAR, Inc., 10901-C Roosevelt Boulevard, Suite 1000, St. Petersburg, FL 33716. Available from NCADI.

#### Michigan Alcoholism Screening Test (MAST)

- The MAST was one of the earliest instruments designed to detect alcoholism. It originally consisted of 25 questions that could be administered in 10 to 15 minutes. It was subsequently revised to a 24-question instrument that can be rapidly administered by professional as well as nonprofessional staff. A Short Michigan Alcoholism Screening Test (SMAST), consisting of 13 items, was designed to be self-administered and easily scored.
  - Source: Selzer, M. L.; Vinokur, A.; and van Rooijen, L. A self-administered short Michigan Alcoholism Screening Test (SMAST). Commented out ElementJournal of Studies on Alcohol 36(1):117-126, 1975.

#### New York State Alcohol and Health Self-Test

- This test gathers information on alcohol use and may signal the presence of emotional problems. It can be completed by the patient or by a staff member.
  - Source: New York State Division of Alcoholism and Alcohol Abuse, 194 Washington Avenue, Albany, NY 12210. Available from NCADI.

#### Perinatal Substance Abuse Assessment Tool

- This six-page, broad-based questionnaire covers such areas as alcohol and other drug use, psychosocial history, and current relationships.
  - Source: Santa Clara County Health Department, Bureau of Alcohol and Drug Programs, 2220 Moorpark Avenue, Building H-10, San Jose, CA 95128. Available from NCADI.

#### T-ACE

- The T-ACE questionnaire is a four-item instrument appropriate for detecting heavy alcohol use in pregnant women.
  - Source: Sokol, R.J.; Martier, S.S.; and Ager, J.W. The T-ACE questions: Practical prenatal detection of risk-drinking. Commented out ElementAmerican Journal of Obstetrics and Gynecology 160:863-870, 1989.

#### Ten-Question Drinking History

- These questions explore how much and how often a woman drinks and changes in drinking habits during the past year.
  - Source: Rosett, H.L.; Weiner, L.; and Edelin, K.C. Fetal Alcohol Education Program, Boston University School of Medicine, 7 Kent Street, Brookline, MA 02146. Available from NCADI.

### Parenting Skills Instruments

#### The Adult-Adolescent Parenting Inventory (AAPI)

- The AAPI is used to assess the parenting attitudes and child rearing practices of adolescents and adults. Responses on the AAPI provide a profile of parenting strengths and areas needing improvement.
  - Source: Family Development Resources, Inc., 3160 Pinebrook Road, Park City, UT 84060. 1-800-688-5822.

#### Parenting Interest Questionnaire

- This two-page questionnaire identifies a client's interest level on various parenting topics.
  - Source: Emory University School of Medicine, Clinical and Applied Research, 1256 Briarcliff Road, N.E., Atlanta, GA 30306. Available from NCADI.

### Psychiatric Assessment Instruments

#### Beck Depression Inventory

- This 21-item inventory is used to assess the intensity of depression in psychiatrically diagnosed patients and to detect possible depression in populations.
  - Source: The Psychological Corporation, Order Service Center, P.O. Box 839954, San Antonio, TX 78283-3954. 1-800-228-0752.

#### Center for Epidemiologic Studies Depression (CES-D) Scale

- This 20-item, self-report scale is designed to measure depression symptoms. The items on the CES-D scale were chosen from previously validated scales.
  - Source: National Institute of Mental Health, National Institutes of Health, Bethesda, MD 20892. Available from NCADI.

#### SCL-90-R

- This instrument is a multidimensional, self-report, symptom inventory designed as a screening/ outcome measure for psychopathology.
  - Source: Clinical Psychometric Research, Inc., P.O. Box 619, Riderwood, MD 21139. 1-800-245-0277.