# Appendix A—Training Guidelines for Programs

The training received by program staff helps to determine the quality of services that can be offered by programs serving pregnant, substance-using women and their families. The array of problems confronting these women suggests that training must be continuous.

The process should begin with an assessment of the training needs of staff and result in a goal-oriented training plan. Training resources are often close at hand. Program staff should be canvassed for the skills and knowledge they possess. Personnel of other community programs represent a wealth of expertise often waiting to be tapped. Community-based, collaborative training activities offer the added benefit of strengthening the networks that serve pregnant, substance-using women and their children.

## Training Teams

The expertise of members of a training team should vary depending on the subject of the particular training being developed or delivered. Training teams may include a health educator (to develop curricula), nutritionist, social worker, public health nurse, certified alcoholism and drug counselor, program administrator, physician, and mental health counselor.

### Training Areas

Training for medical staff, alcohol and other drug treatment providers, and others serving pregnant, substance-using women and their children should address these topics:

#### Diagnosis and treatment

- Medical guidelines -- basics of prenatal, labor and delivery, perinatal, and postpartum care
- Treatment readiness in substance-using women -- understanding aspects of the woman's readiness and/or motivation for treatment
- Assessment instruments -- uses and benefits of various instruments to measure substance use, as well as psychosocial, psychiatric, and parental functioning
- Dual diagnosis -- techniques for assessment and diagnosis, and treatment planning for mentally impaired, substance-using pregnant women
- Women with positive toxicology screens in alcohol and other drug treatment programs -- procedures for referral, counseling, and followup. Ideally, pregnant women should not be discharged from treatment programs or from prenatal care services because of continual substance use.
- Followup care -- approaches for relapse prevention, monitoring, and intervention

#### Federal/State guidelines and requirements

- Federal and State guidelines for alcohol and other drug treatment—techniques for assessment and diagnosis, treatment planning, monitoring, and followup care
- Confidentiality and reporting -- requirements to report alcohol and other drug use and child abuse and neglect; Federal and State confidentiality provisions
- Urine toxicology screening -- procedures for and implications of screening, and the importance of informed consent
- Legal issues -- approaches for coping with outstanding warrants, domestic violence, child custody, adoption, foster care, and divorce

#### Population-specific issues

- Child abuse and neglect -- supportive counseling techniques for improved client functioning and healing, both for the adult or teenage client and for her children
- Noncompliant patients -- procedures for the protection of the health and well-being of the mother and child
- Gender-specific treatment -- discussion of the special needs of women for transportation, child care, financial support, safe housing, prenatal and postpartum care, issues of sexuality and skills training regarding how to negotiate for safer sex, and sexual abuse and victimization counseling
- Sociocultural sensitivity -- discussion of the strengths and challenges presented by race, culture, and socioeconomic circumstances
- Incest, adult and child sexual abuse -- discussion of the impact of abuse and issues of anger, fear, and self-esteem
- Domestic violence -- discussion of safety concerns, self-worth, independence, legal action, and alternative living environments
- Habilitation and rehabilitation -- education of patients in tasks of daily living, skill development, and behavior change
- Child development -- discussion of developmental stages, problems, and the special needs of children of substance-using mothers

#### Case management

- Case management—definition of role and function, as well as measures of performance
- Coordinating medical and social services -- conditions for referral, reporting, monitoring, and coordination of patient care
- Documentation -- preparation and management of medical charts and case records
- Ethics -- discussion of values and principles underlying the continuum of care and provider responsibilities to the client and the community

#### Community networking

- Developing cooperative agreements between medical, alcohol and other drug treatment, and social service programs -- formal and informal approaches and mechanisms to develop cooperative agreements
- Community services -- discussion of the types of services available, eligibility requirements, and barriers to service
- Outreach -- identification and recruitment of clients into care

#### Staff development

- Multidisciplinary team approach—discussion of roles, communication, conflict resolution, and team-building techniques
- Staff development and burnout -- identification of the causes of and techniques to reduce stress; creation of professional growth opportunities

#### Infectious diseases

- HIV antibody counseling and testing -- procedures for the protection of patients and program staff and approaches for supportive care
- Infectious diseases of drug users -- discussion of the signs and symptoms of disease, particularly sexually transmitted diseases, blood-borne infections (e.g., hepatitis B and C), and tuberculosis, and approaches for their prevention and treatment