# Consensus Panel

Chair
- Donald R. Wesson, M.D.
- Scientific Director
- MPI Treatment Services
- Summit Medical Center
- Oakland, California

Facilitators
- Mary R. Haack, R.N., Ph.D.
- Senior Research Scientist
- Center for Health Policy Research
- The George Washington University
- Washington, D.C.
- Karen Larson, R.N., B.S.N.
- Assistant Director
- Division of Alcohol and Drug Abuse
- North Dakota Department of Human Services
- Bismarck, North Dakota
- Dorothy B. North, N.C.A.C. II, C.E.A.P.
- Chief Executive Officer
- Vitality Center
- Elko, Nevada
- Bonnie Baird Wilford, M.S.
- Director
- Pharmaceutical Policy Research Center
- Intergovernmental Health Policy Project
- The George Washington University
- Washington, D.C.

Workgroup Members
- Margaret Kent Brooks, J.D.
- Consultant
- Montclair, New Jersey
- Margaret A. Compton, R.N., Ph.D.
- Post-Doctoral Fellow
- UCLA Drug Abuse Research Center
- Neuropsychiatric Institute
- Los Angeles, California
- Archie S. Golden, M.D., M.P.H.
- Director
- Adolescent Substance Abuse Program and
- Chairman
- Department of Pediatrics
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland
- Richard Harris, R.C.S.W.
- Director of Housing and Chemical Dependency Services
- Central City Concern
- Portland, Oregon
- Albert E. Jones, L.C.S.W.
- Program Director
- New Directions, Inc.
- Memphis, Tennessee
- Walter Ling, M.D.
- Director
- Los Angeles Addiction Treatment Research Center and
- Associate Chief of Psychiatry for Substance Abuse
- West Los Angeles Veterans Administration Medical Center and
- Professor
- Chief of Substance Abuse Program
- University of California, Los Angeles (UCLA)
- Los Angeles, California
- Carole A. Madden, R.N., B.S.N., C.D.
- Coordinator of Intervention Services
- North Arundel Hospital
- Glen Burnie, Maryland
- John Melbourne, M.D.
- Medical Director
- Chemical Dependency Services
- Danbury Hospital
- Danbury, Connecticut
- David E. Smith, M.D.
- Medical Director
- Haight Ashbury Free Clinics
- Training and Education Project
- San Francisco, California
- Lovetta L. Smith, R.N., D.N.Sc., F.A.A.N. 1
  1. Lovetta Smith, R.N., D.N.Sc., F.A.A.N., was originally cochair for this TIP but had to withdraw. Her contributions as cochair are appreciated. Dr. Smith also served as a field reviewer for the document.
- Associate Chief of Nursing Service
- Surgical and Special Care Service
- Gainesville Veterans Administration Medical Center
- Gainesville, Florida