# Chapter 6—Costs and Current Payment Mechanisms for AOD Detoxification

In the United States, alcohol and other drug (AOD) detoxification services are provided in many different settings: general medical and psychiatric hospitals, inpatient AOD treatment programs, outpatient clinics, and social model detoxification programs. There is no one national reporting system that tallies the number of detoxification episodes each year in the United States. Discussions of the costs associated with detoxification must address the following considerations:

- In a general medical hospital, detoxification may be provided incidentally to treatment of injuries or complications of AOD dependence.
- Detoxification services may not be documented in the medical records or through insurance billing because the indication of AOD abuse may jeopardize insurance coverage and may alter the confidentiality requirements for the records.
- Methadone and other drug treatment clinics often provide detoxification services as a component of comprehensive treatment.
- State reporting systems do not distinguish admissions that involve detoxification.

Given the uncertainties inherent in estimating the number of detoxification episodes and the settings in which they occur, the annual cost of detoxification services in the United States is unknown.

## Current Sources of Funding for AOD Services

### Overview of the Public Funding System

Current patterns of funding for AOD treatment are poorly coordinated and inflexible. The percentage of public funding earmarked for treatment has never been able to keep pace with demand. The following areas are of key concern:

- The need for coordination. More than three dozen Federal agencies fund AOD abuse treatment programs. No formal system exists to coordinate Federal agency activities. Furthermore, more than 75 congressional committees or subcommittees have oversight and funding authority over AOD abuse programs (Wilford, 1993).
- The need for flexibility. Many Federal programs are categorical. This approach restricts efforts to construct an integrated, comprehensive treatment system. Ancillary service components such as transportation and child care are overlooked, and in their absence clients are unable to gain access to available treatment services (Center for Health Policy Research, 1993).
- The need for improved access. Medicaid, one of the most promising sources of funding for AOD services, is difficult to use Center for Health Policy Research, 1993; Wilford, 1993).

### Federal Funding

#### The Substance Abuse and Mental Health Services Administration

The Substance Abuse and Mental Health Service Administration (SAMHSA), an agency of the Department of Health and Human Services (DHHS) , is the major source Federal support for treatment and related services for persons who are mentally ill or chemically dependent. SAMHSA is composed of three agencies: (1) the Center for Substance Abuse Treatment (CSAT), (2) the Center for Substance Abuse Prevention, and (3) the Center for Mental Health Services.

SAMHSA administers the DHHS AOD block grant program, which is the primary source of long-term Federal funding to the States for publicly supported AOD abuse treatment and prevention programs. In creating SAMHSA in 1992, Congress divided the block grant program into two parts: one for mental health and one for substance abuse prevention and treatment. The latter was authorized at $1.13 billion for fiscal year 1993, of which 35 percent was targeted to alcohol abuse services, 35 percent to drug abuse services, and 20 percent to prevention. Half of the remaining 10 percent was earmarked as a set-aside for special programs. Currently, this set-aside targets pregnant women and women with dependent children. According to the Center for Health Policy Research (CHPR), the remaining 5 percent was used by SAMHSA for technical assistance, data collection, program evaluation, and the creation of a national prevention database (Center for Health Policy Research, 1993).

Block grant funds are awarded to the single State agency in each State. The States distribute the funds according to their own priorities, within established Federal guidelines. Each State that receives block grant funds is required to submit a plan to the Federal Government. This plan must incorporate input from the public. Allocation procedures at the State level vary considerably. Each State, moreover, has a different format for reporting use of funds; consequently, tracking resource allocation and use of set-asides is difficult.

Categorical SAMHSA programs that may provide support for detoxification services include CSAT's Capacity Expansion Program, Cooperative Agreements for Drug Abuse Treatment Improvement -- Campus Treatment Program, and Cooperative Agreements for Drug Abuse Treatment Improvement in Crisis Areas (Target Cities) Program. CSAT's major demonstration program for Pregnant and Postpartum Women and Their Infants does not cover detoxification services. (For detailed information on CSAT programs, please contact the appropriate program division. See Appendix C for addresses and phone numbers.)

#### Other Federal Support

Categorical programs from other Federal Agencies may also provide services as part of a comprehensive health model. Information on these programs may be found in a report titled An Analysis of Resources to Aid Drug-Exposed Infants and Their Families (Center for Health Policy Research, 1993), as well as in directories of Federal grant and contract assistance programs.

### State Funding: Medicaid

Medicaid is a cooperative Federal and State program that is administered by the Health Care Financing Administration. Medicaid is an entitlement program and therefore is not subject to the congressional appropriations process. States receive Federal contributions based on per capita income; in poorer States, the Federal contribution may be as high as 83 percent -- in wealthier States, 50 percent. States may increase the Federal match by voluntarily raising their contribution to the program. The States participate in Medicaid voluntarily and administer the program within broad Federal guidelines. Eligibility requirements, covered benefits, and provider payment mechanisms vary enormously.

Although not designed to fund AOD abuse treatment services, Medicaid has become the most stable source of funding for such services. Medicaid reimbursement for AOD abuse treatment doubled between 1982 and 1987 (Center for Health Policy Research, 1993; Wilford, 1993). As with the overall program, there is little consistency from State to State with regard to individual coverage for AOD abuse treatment or the treatment settings for which services are reimbursed. Federal statutes stipulate that Medicaid is to cover "medical and remedial" services. It will cover most hospital-based services. In regard to AOD abuse treatment services, for example, a majority of States may cover a hospital stay for a 3- to 6-day inpatient detoxification and a limited number of visits for followup outpatient counseling (Center for Health Policy Research, 1993). To improve access to extended treatment, Gates, (1992) suggested that States reimburse for detoxification services contingent on coordination with long-term treatment placement or that they design specialized case-management services as part of the State plan.

Medicaid beneficiaries have few long-term options for coverage of AOD abuse treatment. This lack may contribute to the cycle of relapse and return to episodic hospital-based detoxification for some persons. Medicaid inpatient payment statistics reflect the unrealistic structure of the Medicaid reimbursement system. In fiscal 1994, the portion of Medicaid hospital costs attributable to AOD abuse treatment is expected to exceed $7.4 billion. Approximately 20 percent of annual Medicaid expenditures for hospital care are associated with substance abuse (Center on Addiction and Substance Abuse at Columbia University, 1993).

Many States are discouraged by the complex regulations that govern Medicaid. Some application procedures make it difficult for individuals to obtain benefits. Other States have responded creatively to the challenge (Center for Health Policy Research, 1993).

States also have demonstrated resourcefulness in developing ways to raise State revenue and thereby gain access to additional Medicaid funding (Gates, 1992). One technique is to transfer general State revenues intended for AOD services to the State Medicaid agency rather than to the State Division of Alcohol and Drug Abuse. The transferred funds become eligible for the Federal match. Some States apply revenues from alcohol excise taxes to their Medicaid match funds. Some States allow persons filing income tax returns to designate that a portion of their refunds be directed to AOD abuse treatment. Still others have enacted laws under which revenue generated by the sale of property confiscated during convictions for drug-related crimes are applied to the Medicaid match. And some practices are under close scrutiny by Federal agencies and may not have produced long-term solutions that are viable or cost effective.

### Funding and State Health Care Reform

Health care reform efforts, a matter of major debate at the Federal level at the time this consensus panel convened, are having a strong impact on clinical practice. Many States have already taken the lead in health care reform. Since the national health care reform act was not passed by Congress, States will continue to develop reform strategies consistent with a managed care environment. In all likelihood, the primary efforts for health care reform effort will proceed individually, State-by-State, rather than on a national basis.

Facing growing financial pressures to contain costs, many States have enacted comprehensive health care reform legislation. Coverage for addictive disorders has been the subject of extensive State house debate; "of more than 70 major reform bills considered in 45 States during 1993, two thirds contained some benefits for AOD abuse treatment" (Callahan, 1994).

## Toward a Model AOD Detoxification Services and Benefits System

Drawing on clinical experience, the continuum of care set forth in the CHPR Model, and an appreciation of fiscal realities, the panelists agreed that the following principles should govern the design and implementation of AOD detoxification services and benefits systems. Many of the recommendations concerning the number of treatment episodes and lengths of stay are based on the Legal Action Center's Model Legislation Mandating a National Health Insurance Benefit for Prevention and Treatment for Alcoholism and Drug Addiction (Legal Action Center, 1993).

Each client should be assessed before entering detoxification. The severity of predicted withdrawal symptoms, the intensity of care needed to ensure appropriate management, and identified psychosocial and family-support needs should determine the selection of treatment setting and the duration and type of services offered.

A majority of patients safely undergo detoxification without being admitted either to a hospital or to a residential setting. Nonetheless, patients' clinical and other needs, not the likelihood for reimbursement, should govern the choice of treatment setting. Inpatient detoxification should not be arbitrarily limited, for example, to patients with concurrent psychiatric problems.

The care system should be grounded in the understanding that individuals entering AOD detoxification programs have diverse and wide-ranging needs. While most patients will not require every available service, the system should be structured to meet each discrete need as well as any combination of needs. In most cases, development of such a structure will require the creation of a system of referral and interagency linkages. Timely and dependable communication among such agencies is essential. If, for example, a woman who has primary child care responsibilities enters a residential detoxification setting or is admitted to a hospital, appropriate child care services, possibly including room and board, should be available.

Ideally, there should be no caps on the number of covered inpatient detoxification episodes and no limits on length of stay. At a minimum, each participant in a health benefits plan should be eligible for 10 days of treatment in a hospital, nonhospital, or ambulatory detoxification program, as medically necessary, during any calendar year. If medical conditions require additional lengths of stay, benefits should be available.

Alcoholism is a chronic disease, and most alcoholics will experience at least one relapse. Some patients experience several detoxification episodes before they enter long-term treatment and achieve lasting abstinence. Given this reality, no arbitrary limits should be placed upon the number of detoxification episodes for which a patient will receive reimbursement or upon the length of these episodes.

- Ideally, health plans should provide benefits that ensure short-term inpatient treatment (30 days per year) in a hospital or freestanding facility, as well as long-term treatment (up to 18 months) in residential programs for persons who have undergone AOD detoxification.
- Outpatient treatment options should be broad. Within any calendar year, they should include, at a minimum, as many as 160 days of intensive and/or nonintensive outpatient visits and as many as 60 family outpatient visits.
- Planners must examine the issue of client copayments.

One view holds that even a modest copayment may pose a burden to many clients and may discourage those initially seeking services as well as those patients remaining in aftercare. Others believe that revenue gained from such payments may be more than offset by the negative effect on patient retention rates and, in the long term, recidivism. However, some clinicians believe that even modest copayments reinforce the notion of commitment to treatment. Requiring patients to pay something may assign to treatment an importance equal to that of abusing AODs. Clinicians who hold this view do not necessarily recommend full copayments as an effort to raise revenue because they are aware that, especially in public sector programs, most clients lack the financial means to pay. They argue that

- Case management and pharmacotherapeutic intervention should be offered to all patients, as clinically appropriate
- Benefit plans should cover the provision of patient and family education programs in all detoxification settings; human immunodeficiency virus/acquired immonodeficiency syndrome education is especially important
- Benefit plans must include provisions for appropriate utilization review. Uniform patient placement criteria for AOD detoxification services should be developed and used to support the utilization-review process; utilization review should be performed only by individuals who have adequate knowledge of AOD treatment issues.

Some States, including Oregon and Massachusetts, have begun to develop patient placement criteria based on the American Society of Addiction Medicine model (Hoffman, 1991) and to tailor them to local needs. Properly used, such criteria ensure greater uniformity in care and more appropriate and cost-effective allocation of resources. They provide a safety net that protects the client from falling to an inappropriate level of care.

Patient placement criteria, however, may be subject to misinterpretation. For example, should a criteria set support a specific detoxification setting under well-specified conditions, benefits managers might seize on that recommendation to the exclusion of others and use it to justify expansion of lower cost and potentially inappropriate services. Individual clinical need as the primary concern in patient placement cannot be overemphasized.

Unregulated utilization review decisions by health professionals who are not experienced in AOD issues and treatment have led to the denial of needed AOD abuse treatment services and inappropriately restricted lengths of stay. Improperly performed and regulated, utilization review may be counterproductive and may ultimately increase the costs associated with AOD abuse.

Health care providers, administrators, benefits managers, and legislators should examine the merits of developing new configurations for the delivery of AOD detoxification services. New, intermediate-level service configurations are needed that will bridge service gaps and ensure cost-effective, high-quality delivery of care. Issues associated with the development of such settings, including allocation of staff, licensing requirements, prescribing authority, and interagency networking, should be explored.

## A Model for Estimating the Cost of AOD Abuse Treatment

The panel discussed various models available in the literature that service providers and administrators may use in developing cost estimates. One model they found particularly useful can be found in the book Treating Drug Problems (Gerstein and Harwood, 1990). The authors present and illustrate the use of a formula for estimating the cost of AOD abuse treatment.

The process begins with the acknowledgment that it is impossible to meet all needs. As treatment resources are limited, providers must establish priorities to ensure the optimum use of energy and financial resources. The authors developed an estimate for expansion of public coverage of certain AOD abuse treatment services nationwide and recommended consideration of the following four priorities as quoted below:

- "End delays in admission when treatment is appropriate, as evidenced by waiting lists
- "Improve treatment (by raising the levels of service intensity, personnel quality and experience, and retention rates of existing modalities; by having programs assume more integrative roles with respect to related services; and by instituting systematic performance monitoring and follow-up)
- "Expand treatment through more aggressive outreach to pregnant women and young mothers, as this could result in a great reduction of external social costs
- "Further expand community-based and institutionally based treatment services to provide treatment of criminal justice clients."

Next, the model suggests three strategic options for attaining service delivery goals:

- A core strategy to deal with existing waiting lists, remedy deficiencies in program quality and management, and implement modest program initiatives for young women and children
- A comprehensive strategy, adding to the core plan a substantially greater induction of criminal justice clients and a more ambitious plan for treating drug-abusing and drug-dependent mothers. This comprehensive plan would . . . provide the optimal level of public treatment resources
- An intermediate strategy to be enacted between the core and comprehensive approaches.

Having established quantifiable targets (such as "Increase daily treatment enrollment by 66,000") and using documented sources to develop assumptions about variables such as capital costs, training needs, and the number of individuals who could be expected to enter treatment, the authors estimate the cost of services to meet the four goals under each of the three strategies (Gerstein and Harwood, 1990).

## Estimated Costs Based on Field Review Data

Field reviewers of the Treatment Improvement Protocol (TIP) were asked to provide specific cost data for a model detoxification program, a social model detoxification program, and an intensive outpatient program. Some general information on medical model and social model detoxification programs is included in this TIP in 6-2, and 6-3. Data on intensive outpatient costs are not included as there is a comprehensive section on costing for this type of treatment program in the TIP titled Intensive Outpatient Treatment for Alcohol and Other Drug Abuse (TIP 8; Center for Substance Abuse, 1994).

The cost data presented here are based on information provided from field reviewers in six different regions of the country and include both private and public programs. The types of the represented localities are rural, suburban, and urban. Because of regional and programmatic differences, it is not possible to ascertain definitive costs for the delivery of detoxification services. The actual costs vary considerably depending on the size of the program, the rent or purchase price of treatment facilities, and varying labor costs from one region of the country to another. Costs are examples only but may provide useful estimates of these models of detoxification services. It is important to emphasize that the cost data that appear in 6-2, and 6-3 were not gathered in a controlled study. The following marks indicate characteristics of the programs represented by the exhibits:

*Described by program director as modified medical model, not necessarily consistent with the modified medical model discussed in the TIP. (Costs are estimates for 20 beds based on actual experience with a six-bed program. Estimates and costs reflect a 90 percent utilization rate.)

**Represents the number of clients/patients that can be treated at one time.

***Includes admissions not over 24 hours.

Exhibit 6-1: Detoxification Programs--Sample Program Data

Detoxification Programs--Sample Program Data
Program Identification No. | 1 | 2 | 3 | 4 | 5 | 6
Program Type
Medical Subacute | | X | X | | | X
Social Model | X | | | X | X | X
Modified Medical | | | | X*
Region | Northeast | MidAtlantic | Midwest | West | Northwest | South
Locale | Small Metropolitan | Suburban | Large Metropolitan | Rural | Rural | Large Metropolitan
Medical Model
Daily Residential Capacity** | | 14*** | 3-5 | 20 | | 25
Annual Census*** | | 900 (9 mo.) | 550 | 875 * | | 250
Social Model
Daily Residential Capacity** | 8 | | | 20 * | 4 | 25
Annual Census*** | 350 | | | 875 * | 190-250 | 250
Institutional Status | Private Nonprofit | Public Nonprofit | Private Nonprofit | Private Nonprofit | Private Nonprofit | Private Nonprofit

Exhibit 6-2: Projected Annual Budget Sample

Projected Annual Budget Sample Social Model Detoxification Program
Program Identification No. | 1 | 4 | 5 | 6
Core Staffing Costs/FTEs
Registered Nurse | $42,341.00 (2) | $11,326.00 (.33) | 0 | $78,000.00 (3)
Aide | 45,645.00 (3) | 140,00.00 (10) | 0 | 37,440.00 (3)
Addictions Counselor | 15,500.00 (1) | 52,000.00 (2) | $68,352.00 (3) | 37,000.00 (2)
Social Worker | 0 | 0 | 3,000.00 (.25) | 26,000.00 (1)
Financial Benefits Manager | 0 | 5,000.00 (.25) | | 22,500.00 (1)
Total Core Staffing | $104,486.00 (6) | $208,326.00 (12.58) | 71,352.00 | $200,940.00
Payroll Taxes and Benefits | 17,890.00 | 47,915.00 | 14,800.00 | 40,188.00
Consultant Physician | 1,020.00 | 12,000.00 (.12) | 840.00 | 0
Direct Operating Costs
Supplies (office/activities) | (in admin.) | 6,445.00 | 2,200.00 | 5,000.00
Meds, lab fees, contr. services | 6,700.00 | 1,100.00 | 360.00 | 30,000.00
Telephone | 3,130.00 | 3,255.00 | 720.00 | 6,000.00
Vehicle | 0 | 2,000.00 | 0 | 500.00
Accounting/Legal Expense | (in admin.) | 1,953.00 | 300.00 | 6,000.00
Staff Development | 1,725.00 | 2,000.00 | 600.00 | 3,000.00
Office and Postage | (in admin.) | 3,075.00 | 500.00 | 3,000.00
Equipment | 1,345.00 | 2,500.00 | 450.00 | 5,000.00
Local Travel | 400.00 | 2,475.00 | 1,685.00 | 3,000.00
Miscellaneous | 575.00 | 10,485.00 | 250.00 | 800.00
Administrative Mgmt. | 5,640.00 | 30,342.00 | 2,400.00 (1) | 70,000.00
Facility
Building | 27,100.00 | 72,000.00 | 6,000.00 | 0
Food | 15,590.00 | 39,600.00 | 2,800.00 | 30,000.00
Maintenance | 3,690.00 | 4,800.00 | 1,000.00 | 5,000.00
TOTAL COSTS | $189,311.00 | $450,271.00 | $106,257.00 | $408,428.00

Exhibit 6-3: Projected Annual Budget Sample Medical Model Detoxification Program

Projected Annual Budget Sample Medical Model Detoxification Program
Program Identification No. | 2 | 3 | 4* | 6
Core Staffing Costs/FTEs | | | (Modified medical)*
Registered Nurse | $288,000.00 (8) | 0 | $33,000.00 (1) | $78,000.00 (3)
Aide | 80,000.00 (4) | $71,400.00 (5) | 140,000.00 (10) | 37,440.00 (3)
Addictions Counselor | 77,000.00 (3) | 0 | 52,000.00 (2) | 18,500.00 (1)
Social Worker | 40,000.00 (1) | 40,000.00 (2) | 15,000.00 (.5) | 26,000.00 (1)
Financial Benefits Mgr. | 21,000.00 (1) | 0 | 5,000.00 (.25) | 22,500.00 (1)
Total Core Staffing | $506,000.00 (17) | $111,400.00 (7) | $245,000.00 (13.75) | $182,440.00 (9)
Payroll Taxes and Benefits | 197,000.00 | 34,035.00 | 56,350.00 | 36,488.00
Consultant Physician | 26,000.00 (.4) | 18,548.00 | 25,000.00 (.25) | 0
Direct Operating Costs
Supplies (office/activities) | 4,000.00 | 163,983.00 | 6,445.00 | 5,000.00
Meds, lab fees, contr. services | 105,000.00 | (none given) | 5,000.00 | 30,000.00
Telephone | 5,000.00 | 3,937.22 | 3,255.00 | 6,000.00
Vehicle | 4,000.00 | 3,748.75 | 2,000.00 | 500.00
Accounting/Legal Expense | 28,000.00 | (none given) | 1,953.00 | 6,000.00
Staff Development | 8,000.00 | 1,148.84 | 2,000.00 | 3,000.00
Office and Postage | 6,000.00 | 869.59 | 3,075.00 | 3,000.00
Equipment | 10,000.00 | (none given) | 2,500.00 | 5,000.00
Local Travel | 2,000.00 | (none given) | 2,475.00 | 2,500.00
Miscellaneous | 8,000.00 | 264.55 | 50,085.00*** | 6,000.00
Administrative Mgmt. | 56,000.00 | 56,578.00 | 30,342.00 | 70,000.00
Facility
Building | 40,000.00 | 29,600.00 | 90,000.00 | 24,000.00
Food | (in meds., lab, etc.) | (in building) | (in miscellaneous) | (in building)
Maintenance | (in meds., lab, etc.) | (in building) | (in building) | (in building)
TOTAL COSTS | $1,005,000.00 | $425,112.95 | $525,480.00 | $379,928.00