# Chapter 5—Improving Quality and Measuring Outcomes of AOD Detoxification Services

Effective measurement of treatment outcomes has long been a critical issue in the development of the Nation's alcohol and other drug (AOD) abuse treatment system. Studies of methadone maintenance treatment programs indicate that variables such as adequacy of methadone dosing levels, staff turnover rates, and differences among counselors correlate significantly with patient performance. These factors are, nonetheless, rarely taken into account by standard measures of treatment effectiveness (Gerstein and Harwood, 1990).

This chapter provides general information on quality improvement and outcomes measurement. A more detailed discussion of these issues as they relate to AOD abuse treatment is found in another Treatment Improvement Protocol (TIP) in this series, Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment (TIP 14; Center for Substance Abuse Treatment, 1995). It is intended as an aid in developing, implementing, and managing outcome monitoring systems.

## Quality Improvement

### Quality Assurance Checklist

The move toward health care reform and the growing concern for financial accountability have made service providers increasingly aware of the need to ensure quality care. One potentially useful document, prepared by an organization with standing in the addictions field, is a 10-step quality assurance checklist issued by the Joint Commission on Accreditation of Healthcare Organizations (JCAHO) (see Exhibit 5-1).

Exhibit 5-1 JCAHO Quality Assurance Guidelines

JCAHO Quality Assurance Guidelines *

1. Assign responsibility

2. Delineate scope of care and services

3. Identify important aspects of care and services

4. Identify indicators of outcome (no less than two; no more than four)

5. Establish thresholds for evaluation

6. Collect data

7. Evaluate data

8. Take action

9. Assess action taken

10. Communicate

* The Accreditation Manual for Hospitals. Joint Commission on Accreditation of Healthcare Organizations. Oak Brook, Illinois. 1991.

### Quality Improvement Indicators

#### Patient-Based Quality Improvement Indicators

The specific indicators of quality shown in Exhibit 5-1 are of particular importance. Staff can perform chart reviews to verify the quality improvement indicators. Routine weekly reviews of charts of 25 percent of the patients seen, with followup of any problems discussed in weekly case conferences, is a standard recommended by JCAHO (Joint Commission on Accreditation of Healthcare Organizations, 1993). Treatment staff should complete and document each of the following steps in the patient's record. If a step has not been performed, a reason for the omission should be included.

1. Admission procedures
  - Document the level of withdrawal; take previous medical history and drug use history; conduct physical examination; address legal issues; obtain patient consent for treatment
  - Develop an individualized treatment plan
  - Develop and initiate a plan for discharge and aftercare
  - Conduct formal assessment.
2. Primary services
  - Evaluate the patient's physical and psychological status (must include a medical history and physical examination within 24 hours, if these were not performed at admission)
  - Develop a plan documenting the anticipated course of medical and social management
  - Develop a plan for continuing care (involving the patient's family or significant others in treatment, when possible)
  - Perform routine drug screens
  - Flag files to indicate (1) previously treated patients and (2) patients with special medical problems, such as insulin-dependent diabetes, a history of seizures, drug sensitivities, or psychiatric comorbidity
  - Consult previous admission data and treatment plans, if available.
3. Financial information
  - Obtain at admission; seek reauthorizations as required
  - Provide assistance in obtaining entitlements such as Medicaid.
4. Discharge and aftercare
  - Identify patient's continuing needs for medical care, housing, legal assistance, food stamps, child care, or other services
  - Address legal problems (e.g., for court-referred patients)
  - Comply with legal mandates and reporting requirements.

#### Program-Based Quality Improvement Indicators

The programs' internal management information system should include clinical reports, incident reports, followup reports from referral resources, insurance and accreditation reports, and public health and other Government inspection reports. In addition, any other quality-improvement reports that have been generated to analyze trend data drawn from patient charts should be included. Every treatment program should have such a system in place to capture and compile these data so that program administrators can take a step back from reviewing the charts of individual patients to look at the entire patient population. The following indicators should be documented:

- Patient demographic data
- Primary and secondary drugs used at admission
- Sources of referral into the program, plus any changes in referral patterns
- Accuracy and timeliness of intake assessments (e.g., significant problems not identified at initial assessment, changes in the treatment plan, indications that clinical care was not appropriately individualized)
- Admissions processed within designated time frames
- Number of people interviewed who were not admitted (where they went and why)
- Number of individuals on the waiting list for admission and the average length of time on the waiting list (with note made of any changes cyclically and over time)
- Ratio of planned discharges versus the number of patients who left against advice (the case manager's unscheduled discharge report is a key document for this indicator)
- Staff data on training completed, turnover rates, internal promotion and transfer rates, staff complement (overall and by specialized unit), staff credentials, and training relative to job responsibilities and program licensure requirements
- Safety, security, sanitation, and insurance inspection reports
- Financial performance (e.g., evidence that reimbursements are billed accurately and promptly, all eligible funds are applied for, appropriate financial procedures are in place, financial records are in order and independently audited on a regular schedule).

The National Institute on Drug Abuse has published a technology transfer package to help program administrators and staff who have no previous experience or formal training in evaluation to plan and conduct evaluations of their programs. The package is titled How Good Is Your Drug Abuse Treatment Program? and includes an overview and case study manual, an evaluation guide, a resource manual, and looseleaf worksheets and agendas. The procedures and steps discussed in the guide conform to the standards of JCAHO. It is available free of charge from the National Clearinghouse for Alcohol and Drug Information at (800) 729-6686 or (301) 468-2600; TDD (for hearing impaired) at (800) 487-4889.

## Outcomes Measurement

A recent contribution to the literature on addiction treatment is the public policy statement on recommendations for design of treatment efficacy research with emphasis on outcome measures (American Society of Addiction Medicine, 1994a). These recommendations, developed from a consensus process involving more than 70 experts in the addictions field, begin by identifying the nine "essential elements" of studies that assess quality of treatment. They include

- The starting number of patients
- Initial patient characterization
- Comparison with two or more groups
- Description of the treatment program
- Continuing-care compliance, frequency, and duration
- Discharge category
- Number of patients followed up on
- Followup time
- Cost.

Within this framework, the American Society of Addiction Medicine recommends measurement of eight variables, as shown in Exhibit 5-2, but cautions that confirmation of patient self-reports of AOD use or nonuse is desirable, through either biochemical analysis or corroborative reports.

Exhibit 5-2 ASAM-Recommended Variables for Patient Outcome

ASAM-Recommended Variables for Patient Outcome

1. Substance use
  - Status of use of the primary drug of dependence
  - Status of use of other drugs of dependence (including nicotine)
  - History of any use, since the start of treatment, of medications prescribed for their psychotropic action or which have psychotropic side effects
2. Readmission for AOD treatment due to relapse or threatened relapse
3. Health status
  - Use of health services, including illnesses, hospitalizations, and outpatient visits for medical, psychiatric, or dental care since treatment began
  - Confirmatory information (for example, through biochemical markers and standardized interviews)
4. Employment function status
  - Employment status at followup
  - Number (or percent) of days worked compared with days eligible to work
5. Legal problems (during periods when not confined)
  - Driving-under-the-influence violations
  - Arrests
6. Evaluation of the patient's relationship with close family and significant others
  - Status of marital or other partnership relationships
  - Satisfaction with the quality of those relationships
  - Custodial status of children, if any
7. Assessment of global functioning, provided that assessment instruments are appropriately peer reviewed and validated
8. Assessment of psychological (emotional) and social functioning
9. Assessment of major life stressors in the period following treatment

An appropriate system for measuring outcomes, no matter how simple or complex, must also take into account the goals of detoxification. Three desirable goals are to safely manage withdrawal; to engage the patient in treatment; and to provide withdrawal that is humane and respects the patient's dignity. The following list presents detoxification-specific outcomes indicators that are appropriate for these goals and may be used in conjunction with other measures.

### Indicators for Goal 1: To safely manage withdrawal

- Rate of completed detoxification
- Incidence of adverse reactions because of a mistaken diagnosis or assessment
- Deviations from average length of stay for the program under study
- Rates and reasons for incomplete stays (e.g., patients who have transferred from the program or left against advice)
- Rates of patient participation in various program elements
- Numbers of incident reports (e.g., calls to fire or police department)
- Incidence of patient injury.

### Indicators for Goal 2: To engage the patient in treatment

- Percentage of patients for whom discharge and continuing care plans were developed
- Percentage of patients who completed their discharge and continuing care plans
- Reasons for failure to complete plans (analyzed in clusters and trends over time)
- Percentage of patients who have previously completed detoxification with information on salient variables
- Self-reported patient satisfaction with treatment.

### Indicators for Goal 3: To provide patient withdrawal that is humane and respects the patient's dignity

- Number o incidents involving patient rights
- Number of times that patient records were released pursuant to a properly signed consent or court order and the number of incidents in which information was inadvertently released without consent or a compelling court order
- Number of times that patients were deprived of rights that are generally accorded to program participants.