# Appendix G—Field Reviewers

- Reginald A. Alexander, M.D.
- Medical Director
- Alcohol Substance Dependency Treatment Program
- Substance Dependency Treatment Unit
- Veterans Affairs Medical Center
- Des Moines, Iowa

- Douglas L. Bovee, M.D., F.A.C.P.
- Chief of Staff
- Oregon Counseling and Addiction Medicine
- Serenity Lane
- Eugene, Oregon

- Margaret Kent Brooks, J.D.
- Consultant
- Montclair, New Jersey

- Jan L. Campbell, M.D.
- Chief
- Substance Abuse Treatment Unit
- Psychiatry Service
- Veterans Affairs Medical Center
- Kansas City, Missouri

- C. James Coats, A.C.S.W.
- Clinical Social Worker
- Alcohol and Drug Services
- Catholic Human Services
- Traverse City, Michigan

- Margaret A. Compton, R.N., Ph.D.
- Research Scientist
- Los Angeles Addiction Treatment Research Center
- Los Angeles, California

- Susan M. Doyle, R.N., C.A.R.N.
- Program Director
- Shoemaker Center
- Westminster, Maryland

- Larry Egnor, B.A., C.S.A.C.
- Clinical Program Supervisor
- ComCare
- Phoenix, Arizona

- Garland S. Ferguson
- Director
- Division of Detoxification
- Bureau of Alcohol and Drug Abuse Prevention
- Arkansas Department of Health
- Benton, Arkansas

- Bonnie B. Gladden, R.N.
- Detoxification Coordinator
- Keystone Substance Abuse Services
- Rock Hill, South Carolina

- Archie S. Golden, M.D., M.P.H.
- Director
- Adolescent Substance Abuse Program, and
- Chairman
- Department of Pediatrics
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Mary R. Haack, R.N., Ph.D.
- Senior Research Scientist
- Center for Health Policy Research
- The George Washington University
- Washington, D.C.

- Gregory N. Hayner, Pharm.D
- Chief Pharmacist
- Detoxification, Rehabilitation, and Aftercare Project
- Haight Ashbury Free Clinics
- San Francisco, California

- Marc Hertzman, M.D.
- Medical Director
- Department of Psychiatry
- North Arundel Hospital
- Glen Burnie, Maryland

- Timothy James, Ed.M., L.S.A.C.
- Program Director
- Hope House, Incorporated
- Bangor, Maine

- Donald R. Jasinski, M.D.
- Professor of Medicine
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Albert E. Jones, L.C.S.W.
- Program Director
- New Directions, Incorporated
- Memphis, Tennessee

- Linda Kaplan, M.A., C.A.E.
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Martin A. Krepcho, Ph.D.
- Assistant Program Manager, HIV
- Dallas County Health Department
- Dallas, Texas

- Roger A. Kryzanek, M.S.W., L.C.S.W.
- Alcohol/Drug Program Director
- Deschutes County Mental Health Services
- Bend, Oregon

- Jeffrey N. Kushner
- Director
- Oregon Office of Alcohol and Drug Abuse Programs
- Salem, Oregon

- Karen Larson, R.N., B.S.N.
- Assistant Director
- Division of Alcohol and Drug Abuse
- North Dakota Department of Human Services
- Bismarck, North Dakota

- Lawrence S. Linder, M.D., F.A.C.E.P
- Assistant Director
- Emergency Department
- North Arundel Hospital
- Glen Burnie, Maryland

- Kathy Lynn, R.N., M.S., C.S., C.N.A.A.
- Director of Nursing
- Mental Health Division
- North Arundel Hospital
- Glen Burnie, Maryland

- Carole A. Madden, R.N., B.S.N., C.D.
- Chemical Dependency Nurse
- Intervention Services
- North Arundel Hospital
- Glen Burnie, Maryland

- Joan McNamara
- Executive Director
- Gateway, Incorporated
- Tucson, Arizona

- Marilyn Miller, M.A.
- Treatment Consultant
- Center for Substance Abuse Services
- Michigan Department of Public Health
- Lansing, Michigan

- Dorothy B. North, N.C.A.C. II, C.E.A.P.
- Chief Executive Officer
- Vitality Center
- Elko, Nevada

- Janice O'Keefe, R.N., M.P.H., C.A.R.N.
- Director of Clinical Services
- Boston Health Care for the Homeless
- Boston, Massachusetts

- Wayne Raske
- Legislative Liaison/Alcoholism Specialist
- Chemical Dependency Program Division
- Minnesota Department of Human Services
- St. Paul, Minnesota

- Saranne D. Shea, M.S.W., L.I.C.S.W., B.C.D.
- Associates for Counseling
- Brookline, Massachusetts

- Lovetta L. Smith, R.N., D.N.Sc., F.A.A.N.
- Associate Chief of Nursing Services
- Surgical and Special Care Service
- Gainesville Veterans Administration Medical Center
- Gainesville, Florida

- Richard T. Suchinsky, M.D.
- Associate Director
- Addictive Disorders and Psychiatric Rehabilitation
- Department of Veterans Affairs
- Veterans Health Administration
- Washington, D.C.

- John T. Sullivan, M.D.
- Associate Professor of Medicine
- Johns Hopkins University and
- Director
- Center for Chemical Dependence
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland

- Peter L. Washburn, M.D.
- Associate Physician
- Chemical Dependency Recovery Program
- Kaiser Permanente
- San Francisco, California

- James Allen Wilcox, D.O., M.S.
- Associate Professor
- Department of Psychiatry
- Texas Tech University Health Sciences Center
- El Paso, Texas

- Bonnie Baird Wilford, M.S.
- Director
- Pharmaceutical Policy Research Center
- Intergovernmental Health Policy Project
- The George Washington University
- Washington, D.C.

- Bill Wilson, B.S., M.P.A., M.B.A.
- Director
- Behavioral Health
- MPI Treatment Services
- Oakland, California