# Appendix F—Federal Resource Panel

Chair
- Donald R. Wesson, M.D.
- Scientific Director
- MPI Treatment Services
- Summit Medical Center
- Oakland, California

Panel Members
- John Bland
- Public Health Advisor
- Women and Children's Programs Branch
- Division of Clinical Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Janet C. Cleveland, M.S.
- Health Education Specialist
- Training and Technical Support Systems Branch
- Division of HIV/AIDS Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia
- Sandra M. Clunies, M.S., N.C.A.D.C.
- Government Project Officer
- Synthesis Branch
- Office of Evaluation, Scientific Analysis, and Synthesis
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Dorynne Czechowicz, M.D.
- Associate Director
- Medical and Professional Affairs
- Medical Affairs Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland
- Herman I. Diesenhaus, Ph.D.
- Team Leader
- Scientific Analysis Team
- Office of Evaluation, Scientific Analysis, and Synthesis
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Archie S. Golden, M.D., M.P.H.
- Director
- Adolescent Substance Abuse Program and
- Chairman
- Department of Pediatrics
- Johns Hopkins Bayview Medical Center
- Baltimore, Maryland
- Michael Jewell
- Acting Director
- Office of Policy and Planning
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- George Kanuck
- Public Health Analyst
- Program Evaluation Branch
- Office of Scientific Analysis and Evaluation
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Dorothy B. Lewis
- Project Officer
- Clinical Intervention Branch
- Division of Practice and Systems Development
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Robert G. Lubran, M.P.A.
- Branch Chief
- PPG Program Support Branch
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Lynn McQueen, M.S., M.P.H.
- Senior Health Policy Analyst
- Agency for Health Care Policy and Research
- Rockville, Maryland
- Barbara Roberts, Ph.D.
- Senior Policy Analyst
- Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.
- Charles Roberts, Ph.D.
- Statistician
- Scientific Analysis Team
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Terrence Schomburg, Ph.D.
- Public Health Advisor
- PPG Program Support Branch
- Division of State and Community Assistance
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland
- Lovetta L. Smith, R.N., D.N.Sc., F.A.A.N.
- Associate Chief of Nursing Services
- Surgical and Special Care Service
- Gainesville Veterans Administration Medical Center
- Gainesville, Florida
- Richard T. Suchinsky, M.D.
- Associate Director
- Addictive Disorders and Psychiatric Rehabilitation
- Department of Veterans Affairs
- Veterans Health Administration
- Washington, D.C.
- Norma J. Taylor, Ph.D., A.C.S.W.
- Project Director
- National Association of Social Workers
- Washington, D.C.
- Sylvia Trent-Adams, R.N., M.S.
- Public Health Analyst
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- Rockville, Maryland
- Marilyn Vranas, M.S., M.A., R.N., C.S., C.A.R.N.
- Public Health Advisor
- Healthy Start
- Division of Maternal and Child Health
- Health Resources and Services Administration
- Rockville, Maryland
- William E. Woodward, M.D.
- Member, Board of Directors
- American Council on Alcoholism
- Baltimore, Maryland