# Appendix D—Acronyms

AA: Alcoholics Anonymous

AIDS: acquired immunodeficiency syndrome

AMSAODD: American Medical Society on Alcoholism and Other Drug Dependencies (now the American Society of Addiction Medicine [ASAM])

AOD: alcohol and other drug

APA: American Psychiatric Association

ASAM: American Society of Addiction Medicine

ASI: Addiction Severity Index

AZT: azidothymidine

CARF: Commission on Accreditation of Rehabilitation Facilities

CDC: Centers for Disease Control and Prevention

CDRH: chemical dependency recovery hospital

CFR: Code of Federal Regulations

CNS: central nervous system

CSAP: Center for Substance Abuse Prevention

CSAT: Center for Substance Abuse Treatment

DEA: Drug Enforcement Administration

DHHS: Department of Health and Human Services

DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders, edition 3, revised. Superseded in 1994 by DSM-IV-R.

DTs: delirium tremens

FDA: Food and Drug Administration

FR: Federal Register

GC/MS: gas chromatography/mass spectrometry

HBV: hepatitis B virus

HCFA: Health Care Financing Administration

HCV: hepatitis C virus

HIV: human immunodeficiency virus

HUD: Department of Housing and Urban Development

ICD-9: International Classification of Diseases, ninth revision

IND: investigational new drug

IV: intravenous

JCAHO: Joint Commission on Accreditation of Healthcare Organizations

LAAM: levo-alpha-acetylmethadol

NA: Narcotics Anonymous

NAPAN: National Association for the Prevention of Addiction to Narcotics

NCA: National Council on Alcoholism (now the National Council on Alcoholism and Drug Dependency [NCADD])

NCADD: National Council on Alcoholism and Drug Dependency

NIDA: National Institute on Drug Abuse

NIMH: National Institute on Mental Health

ONDCP: Office of National Drug Control Policy

OSHA: Office of Safety and Health Administration

PPD: purified protein derivative

RIA: radioimmunoassay

SAMHSA: Substance Abuse and Mental Health Services Administration

SMA: State Methadone Authority

SSA: single State agency

STD: sexually transmitted disease

TB: tuberculosis

TLC: thin-layer chromatography