# Appendix C—Resource List

The following organizations and agencies provide information and materials that may be useful to staff and clients of alcohol and other drug abuse detoxification programs.

- American Society of Addiction Medicine, 5225 Wisconsin Avenue, NW, Suite 409, Washington, DC 20015; phone: (202) 244-8948; fax: (202) 537-7252.

The American Society of Addiction Medicine (ASAM) is an association of physicians dedicated to improving the treatment of alcoholism and other addictions, educating physicians and medical students, promoting research and prevention, and enlightening the medical community and the public about these issues. ASAM has chapters in 22 States.

ASAM publishes a quarterly medical journal, the Journal of Addictive Disease; a bimonthly newsletter, ASAM News, and practice guidelines such as the ASAM Patient Placement Criteria. It also provides continuing medical education opportunities, including the National Conference on Nicotine Dependence, and the Annual Medical-Scientific Conference. ASAM administers a national certification examination for physicians.

- Center for Substance Abuse Prevention, 5600 Fishers Lane, Rockwall II, Rockville, Maryland 20857; phone:(301) 443-0365.

The Center for Substance Abuse Prevention (CSAP) is part of the Substance Abuse and Mental Health Services Administration of the U.S. Department of Health and Human Services. Until 1992, CSAP was known as the Office for Substance Abuse Prevention, or OSAP.

CSAP's National Clearinghouse for Alcohol and Drug Information (NCADI) distributes printed and audiovisual materials. NCADI coordinates the Regional Alcohol and Drug Awareness Network (RADAR), which facilitates access to State and local sources of information about alcohol, tobacco, and other drugs.

- NCADI, P.O. Box 2345, Rockville, MD 20847-2345; phone: (301) 468-2600 or (800) 729-6686.

CSAP's Resource Center of Substance Abuse Prevention and Disability answers questions about alcohol, tobacco, and other drug abuse prevention and treatment issues for persons with disabilities. Services include customized database searches and fact sheets; phone: (202) 783-2900; TTY/TDD: (202) 737-0725.

CSAP's Drug-Free Workplace Helpline provides telephone consultation, resource referrals, networking services, and publications to business, industry, and unions to assist in planning and implementing drug-free workplace programs; phone: (800) 843-4971.

The CSAP Training System provides training for community prevention workers, health professionals, volunteers, and others; phone: (301) 572-0200.

- Center for Substance Abuse Treatment, 5600 Fishers Lane, Rockwall II Building, Rockville, MD 20857; Division of State and Community Assistance, phone: (301) 443-3820; Office of Scientific Analysis and Evaluation, phone: (301) 443-6549; Division of National Treatment Demonstrations, phone: (301)-443-7745; Division of Clinical Programs, phone: (301) 443-8160.

The Center for Substance Abuse Treatment (CSAT) is part of the Substance Abuse and Mental Health Services Administration of the U.S. Department of Health and Human Services. Until 1992, CSAT was known as the Office for Treatment Improvement, or OTI; phone (English): (800) 662-4357; phone (Spanish): (800) 662-9832.

CSAT and the National Institute on Drug Abuse operate a Drug Abuse Information and Treatment Referral Line that provides information about drug use, treatment, support groups, and services. Information counselors can discuss problems and provide referrals to State and local drug treatment facilities and programs.

- Department of Housing and Urban Development, 451 Seventh Street, SW, Washington, DC 20410; phone: (301) 251-5154 or (800) 245-2691

The Department of Housing and Urban Development (HUD) Office for Drug-Free Neighborhoods offers a helpline that provides information on preventing drug abuse and drug trafficking in public and assisted housing.

- Drug Enforcement Administration, Drug and Chemical Evaluation Section, 600 Army-Navy Drive, Arlington, Virginia 22202; phone: (202) 307-7183.

The Drug Enforcement Administration or DEA provides information about drug regulations.

- Food and Drug Administration, Center for Drug Evaluation and Research, Office of Compliance, Division of Scientific Investigation, Regulatory Management Branch, HFD-342, 7520 Standish Place, Room 115, Rockville, MD 20855, phone:(301) 594-1029.

The Food and Drug Administration (FDA) provides information on Federal regulations concerning use of methadone.

- National Acupuncture Detoxification Association, 349 East 140th Street, Bronx, NY 10454; or 3115 Broadway #51, New York, NY 10027; phone: (718) 993-3100 or (201) 783-3772.

The purpose of the National Acupuncture Detoxification Association (NADA) is to provide training and consultation in the use of acupuncture as an adjunct to AOD treatment. NADA training includes didactic work as well as an apprenticeship program.

NADA sponsors annual educational conferences in the United States and Europe. Full membership in NADA is open only to persons who have completed the training program; however, associate members also are welcome.

- The NADA Literature Clearinghouse, P.O. Box 1927, Vancouver, WA98668-1927; phone: (206) 254-0186; fax: (206) 260-8620.

Distributes written materials, videotapes, and audiotapes.

- Guidepoints: Acupuncture in Recovery, J& M Reports, 7402 NE 58th Street, Vancouver, WA98662-5207; phone:(360) 254-0186.

Guide points: Acupuncture in Recovery is a monthly independent international newsletter offering objective reporting on research, clinical practice, public policy, and clinical matters related to the use of acupuncture in treating addictive and mental disorders. Not affiliated with any advocacy group. Subscriptions cost $180 per year. Reduced rates are available for new subscribers.

- National AIDS Clearinghouse, P.O. Box 6603, Rockville, MD 20850; English Helpline: Phone: (800) 342-AIDS; Spanish Helpline: phone:(800) 344-SIDA; TTY/TDD Helpline: Phone:(800) 243-7889.

Operated by the Centers for Disease Control and Prevention (CDC), the National AIDS Clearinghouse is a central source of information on acquired immunodeficiency syndrome (AIDS) and human immunodeficiency virus infection, including information on the relationship between alcohol and other drug (AOD) abuse and AIDS. Staff have access to educational materials and databases of materials, service organizations, funding sources, and conferences.

- Information on Clinical Trials, phone:(800) 874-2572; Bulk Publications: phone:(800) 458-5231
- National Institute on Drug Abuse, 5600 Fishers Lane, Rockville, MD 20857; phone: (301) 443-1124; fax: (301) 443-7397.

The National Institute on Drug Abuse (NIDA) is part of the National Institutes of Health of the U.S. Department of Health and Human Services. A catalog of training materials in AOD abuse, AIDS, and related areas is available from NIDA's Community and Professional Education Branch.