# Consensus Panel

## Chair:

- David H. Mulligan
- Commissioner
- Massachusetts Department of Public Health
- Executive Office of Health and Human Service
- Boston, Massachusetts

## Facilitators:

- Rosa Lee Black, M.S.W.
- Health Program Specialist
- California Department of Health Services
- Tuberculosis Branch
- Sacramento, California

- Erma E. Cunningham, M.S.W.
- Executive Director/CEO
- Substance Abuse Center of Eastern Kansas, Inc.
- Kansas City, Kansas

- Ronald O. Forbes, M.D.
- Medical Director
- Office of Medical Affairs
- Virginia Department of Mental Health, Mental Retardation and Substance Abuse Services
- Richmond, Virginia

## Workgroup Members:

- Elizabeth M. Breshears
- Chief
- Bureau of Alcohol and Drug Abuse
- Nevada Department of Employment, Training and Rehabilitation
- Carson City, Nevada

- Sue Etkind
- Director
- Division of Tuberculosis Control
- State Lab Institute
- Massachusetts Department of Public Health
- Boston, Massachusetts

- James Gorman, M.S.W., C.S.W.
- Residential Clinical Supervisor
- National Council on Alcoholism
- Lansing Regional Area
- Lansing, Michigan

- Marguerite M. Kiely
- Director
- Substance Abuse Services
- Blue Ridge Community Services
- Roanoke, Virginia

- David J. Mactas
- President
- Marathon, Inc.
- Providence, Rhode Island
- (Currently, Director, Center for Substance Abuse Treatment, Rockville, Maryland)

- Francis A. McCorry, Ph.D.
- Director
- HIV Services
- New York State Office of Alcoholism and Substance Abuse Services
- New York, New York

- Frances M. Moellman, R.N., M.N.
- Program Manager
- Certification Section
- Division of Alcohol and Substance Abuse
- Department of Social and Health Services
- Department of Health Liaison
- Olympia, Washington

- Deborah J. Powers
- IDU/AIDS Treatment Specialist
- Department of Health and Social Services
- Bureau of Substance Abuse Services
- State of Wisconsin
- Madison, Wisconsin

- Renslow Sherer, M.D.
- Director
- Cook County HIV Primary Care Center
- Cook County Bureau of Health Services
- Chicago, Illinois

- Rita Sullivan, Ph.D.
- Director
- OnTrack, Inc.
- Medford, Oregon

- Bruce Thomasson
- Administrator
- AIDS Surveillance Unit
- Arkansas Department of Health
- Little Rock, Arkansas