# Chapter 6—Toward a Safe Workplace

Substance abuse programs must have and implement a TB infection control policy for the early detection, isolation, and treatment of patients or employees with active TB. An effective TB infection control policy will need to be in writing, will identify the person or persons responsible for supervising the implementation of the necessary controls, and will explain and emphasize the hierarchy of controls. The hierarchy of controls will include administrative controls, engineering controls, and, where necessary, masks (or personal respiratory protection). For smaller programs or programs with limited resources, the implementation of an effective TB infection control policy will depend on the program's ability to draw on the expertise and resources of local public health and occupational safety authorities. In devising a TB infection control policy, AOD employers must remember that a safe workplace is not only an ethical and legal obligation that benefits all concerned, it is the predicate for effective AOD treatment.

## How Do We Determine the Risk of TB in a Particular Facility?

The measures a program will take to prevent the transmission of TB will depend on the incidence of TB among first, the surrounding population; second, its patients; and, third, its employees. The higher the incidence, the greater the risk of TB in the program. As the risk of TB increases, so will the intensity of the TB controls employed by the program. In conducting a risk survey, programs should draw on the expertise of local or State public health and occupational safety authorities. Such surveys should be reviewed both periodically and whenever employers have reason to believe that the risk of TB transmission in the facility may be different from what they previously believed, for example, after a nosocomial outbreak.

## What Should a Program's TB Guidelines Say?

A program's TB infection control guidelines should be in writing, should identify the person or persons responsible for implementing it, and should explain and emphasize the hierarchy of controls.

## Who Should Oversee a Program's TB Control Guidelines?

Only properly qualified individuals -- those who are trained about and understand what TB controls are appropriate and needed in their facility -- should be designated to oversee TB controls. A program without such an individual on staff should explore the possibility of obtaining appropriate training through local public health or occupational safety agencies.

## What Is the Hierarchy of Controls?

Both public health and occupational safety authorities recommend a hierarchy of controls in seeking to prevent the transmission of TB in AOD programs, with administrative controls being more important than engineering controls, and engineering controls being more important than masks. This hierarchy of controls is both cost-effective -- since administrative controls can cost very little -- and critical for minimizing the exposure of employees to undiagnosed TB.

### Administrative Controls

Administrative controls are the key for minimizing the occupational acquisition of TB in an AOD program. Administrative controls are intended to result in the early detection of active TB among both patients and employees. Administrative controls will include screening mechanisms, such as patient and new employee questionnaires designed to elicit complete medical histories and to identify risk factors. (See chapter 5 for a discussion of questionnaires.) Administrative controls will also include tuberculin skin testing for new employees and written policies for the referral for evaluation and treatment of those who have positive PPD results.

Administrative controls will emphasize the importance to both patients and staff of identifying, isolating, and treating active disease at the earliest possible instance. Administrative controls will provide for periodic PPD testing and assessment of symptoms or chest x-rays for both patients and staff. In devising administrative controls, programs must proceed from this clear conviction with respect to TB: The best thing any program can do for its patients and staff is to put in place a policy that will result in the prompt identification, isolation, evaluation, and treatment of persons who pose a threat of transmitting the disease to others.

### Engineering Controls

Because of the costs involved, and the expertise required to install and maintain them, the full gamut of engineering controls may not be possible or realistic for many AOD programs. Engineering controls involve developing specifically designated areas that meet the engineering standards for respiratory isolation. Such engineering standards are rigidly defined and are not commonly found, even in most hospitals. They include the use of adequate ventilation systems, high-efficiency particulate air filters, and special ultraviolet lighting in high-risk areas. Those controls are intended to reduce the concentration of infectious droplet nuclei in the air, prevent the transmission of such nuclei throughout the facility, or render the nuclei noninfectious by killing the tubercle bacilli they contain.

Assuming the space and resources, AOD programs in areas where TB and substance abuse are linked should try to develop an area or room with such controls. Such a project should be undertaken only in consultation with environmental engineers from the local or State public health departments or from other appropriate agencies or organizations. Once the appropriate engineering controls are in place, the designated area or room can be used as an isolation or holding area for any patient or applicant who is suspected of having infectious TB. The patient or applicant will remain in this area until he or she can be transferred to a medical facility.

### When Are Masks (or Respirators) Necessary?

Assuming that effective administrative controls are in place, masks are the least important of the three components of the recommended hierarchy of controls. This is at least true for the typical AOD program, since, generally, masks protect only the wearer. Masks are required only when interacting with someone who is or may be infectious, for example, when one is in the same room with such a person or when one is transporting such a person in an enclosed vehicle. Employees who may need to resort to masks to protect themselves must be instructed in their proper use. Masks should also be available for persons who are potentially infectious. Such persons should be isolated and instructed to wear masks and observe other precautions both while awaiting and during transfer to a medical facility. Unless a program functions as a full-service health care facility, employees should not attempt to counsel potentially infectious persons until infectiousness has been ruled out. Programs should contact local occupational safety experts for guidance as to the selection, use, and maintenance of masks, and the development of a respiratory protection program.

## What Can a Program Do To Promote Workplace Safety?

No program which hopes to be effective can evade its legal and ethical obligations to provide a safe workplace. At the same time, it would be unrealistic to expect a field that routinely operates on shoestring budgets to be able to discharge those obligations without outside help. Outside help -- though constrained by the harsh budgetary realities of the mid-1990s -- can be secured through collaboration with local or State public health departments. With or without outside help, all programs should strive to develop TB workplace safety protocols that include the following features.

### New Employees Should Be Screened for TB

New employees should be screened via an appropriately detailed questionnaire and a two-step PPD procedure (see chapter 5). Those with positive PPDs should be evaluated for symptoms and sent for chest x-rays to rule out infectious TB. If a new employee presents with suspected or confirmed infectious TB, he or she should be referred for appropriate evaluation and medical treatment; this employee should not be permitted to begin or return to work until infectious disease is ruled out. Employees should be counseled about the importance of participating in TB screening. Programs should bear the costs of screening procedures or arrange to have screening done by a public health agency. ^1^

1. In dealing with applicants, employers should note that it is illegal to ask about current or past medical conditions, including TB, until after a job offer has been made. Similarly, an employer may not require an applicant to take a physical or other sort of medical examination until after the extension of an offer of employment. Nevertheless, an employer may make the job contingent on a job-related medical examination, and the applicant may be so informed. The purpose of the prohibition on pre-employment medical examinations and inquiries into applicants' medical conditions or histories is to ensure that employers make hiring decisions on the basis of an applicant's current ability to perform job-related functions -- not on the basis of a current, past, or perceived disability.

### Employees Should Be Counseled About the Risk of Acquiring TB on the Job

Employees should be counseled regarding the specific situations that might put them at increased risk for TB. Counseling should occur at the earliest possible point in the hiring process and periodically thereafter. Special attention should be paid to the risks of acquiring TB on the job for those who are immunosuppressed, namely, those with HIV or other immunosuppressing conditions or those on immunosuppressive therapies. Employees (new or continuing) who are at increased risk for TB should be given the option of working in areas where the risk of acquiring TB on the job is minimized. Working in a high-risk situation should be voluntary on the part of the employee. Unless it would cause undue hardship for them, employers must find alternative work for employees if they request transfer to a lower risk work situation. AOD programs must be particularly sensitive to those sorts of accommodations.

### Employees Should Receive Annual PPDs

Employees should be given PPDs annually. Careful records should be kept to identify

on-the-job converters. Employee records should also reflect whether a given employee does or does not have contact with other employees. Such records can help programs to identify inadequacies in their controls. Finally, as with initial screenings, the employee should not have to bear the costs of an annual PPD.

### PPD Conversions Must be Analyzed

Programs must analyze PPD conversions to determine whether conversions are a result of patient contact. If so, this is evidence that a program's administrative and other controls are inadequate, and that the program is seeing patients with unrecognized TB. A program that encounters such problems should review its risk assessment.

### Contact Investigation Policy

Programs should have a contact investigation policy to determine the source of on-the-job exposures to TB. An appropriate policy will provide for:

1. The identification of those exposed to TB on the job
2. PPD testing at baseline and after 12 weeks to identify those who convert as a result of the exposure
3. Evaluation for active disease
4. Referral for treatment or preventive therapy (or provision of same).

### Employee Training on Workplace Safety

Employees should receive annual training on TB and workplace safety. Attendance at such training should be mandatory and should be recorded. The training must be conducted by someone who is versed in both TB and the workplace safety features outlined above. This training should be supplemented by a TB library for both patients and staff. Programs should not rely on videotaped training unless the tapes are presented by someone who can answer employee questions about TB and workplace safety.

### Review of Workplace Safety Practices

Programs should periodically review not only their risk assessments and on-the-job conversion rates, but also their employee infection control practices.

## Programs Must Be Careful Not To Discriminate Against the Disabled

Federal law protects current and prospective employees from discrimination based on disability. Under these laws, AOD programs may not deny or terminate employment on the basis of a person's TB status, unless there is a high probability of substantial harm to others and that probability cannot be reduced or eliminated by some reasonable accommodation. An employer must be willing to make a reasonable accommodation unless to do so would cause an undue hardship. Since a person with infectious TB can be rendered noninfectious in a relatively short time, it is unlikely that any but the smallest program would experience an undue hardship by agreeing to make a reasonable accommodation for an employee, new or old, who has infectious TB.

A reasonable accommodation might mean delaying the start of employment for several weeks or even a couple of months, or giving an employee an extended leave of absence. At any rate, a blanket refusal to hire someone who is infectious but willing to undergo appropriate treatment, or a policy of firing infectious employees who are willing to undergo treatment, would not only be illegal, it would fly in the face of what AOD programs stand for: a chance to recover.

## Programs Must Observe Confidentiality as to Employee Health and TB-Related Information

A properly designed TB workplace safety protocol will generate a variety of records, from questionnaires containing detailed medical histories to logs that document PPD results and occupational exposures to TB. The confidentiality of those records must be observed.