# Chapter 3—The Facts About Tuberculosis

Alcohol and drug treatment programs have an ethical and legal obligation to help prevent the transmission of tuberculosis in their facilities. To meet those obligations, program managers and staff must familiarize themselves -- and their patients -- with the facts about tuberculosis. This chapter outlines the facts regarding the transmission, detection, and treatment of TB.

## Reemergence of Tuberculosis as a Serious National Problem

After declining steadily for about 30 years, the number of new cases of TB reported in the United States began to grow in the mid-1980s. ^1^ From 1985 to 1993, the number of new cases of TB reported in the United States grew by about 14 percent. ^2^ The Centers for Disease Control and Prevention (CDC) attributes that increase to at least four factors:

1. The HIV epidemic
2. Continuing immigration from countries where TB is common
3. The transmission of TB in congregate settings, such as homeless shelters and correctional facilities
4. The deterioration of the Nation's health care infrastructure.

1. For more information about tuberculosis, see Centers for Disease Control and Prevention, U.S. Department of Health and Human Services, Core Curriculum on Tuberculosis: What the Clinician Should Know (3d ed. 1994) [hereinafter referred to as Core Curriculum], and Centers for Disease Control and Prevention, U.S. Department of Health and Human Services, Guidelines for preventing the transmission of Mycobacterium Tuberculosis in health-care facilities, 1994, Morbidity and Mortality Weekly Report 43 (Oct. 28, 1994) [hereinafter referred to as Guidelines], or contact your State or local health department TB program, your State or local American Lung Association, the American Thoracic Society, or the CDC Fax Information Service at (404) 332-4565.

2. Core Curriculum, supra note 1, at 11. There were slightly more than 25,000 new cases of TB reported in 1993. Id. A "case" of TB means a case of active or infectious disease, i.e., TB that can be transmitted to others. That one is infected with TB does not mean that one has active TB disease or is a threat to infect others. Persons who are infected with TB are not necessarily contagious. Only those whose infection develops into active disease will become infectious. The CDC estimates that there are between 10 to 15 million persons infected with TB in the United States. Id. at 13. Only a small percentage of those persons will go on to develop active TB disease and become contagious.

The increase in the incidence of TB has been accompanied by an increase in the incidence of drug-resistant and multidrug-resistant strains of TB (MDR-TB). ^3^ Unlike drug-sensitive strains, drug-resistant TB can be very difficult to treat -- even when the patient is completely adherent to the recommended regimen. ^4^ Persons who develop drug-resistant TB tend to stay infectious longer than those with drug-sensitive strains. They are therefore apt to expose more people to infection.

3. Outbreaks of multidrug-resistant TB have occurred in hospitals and correctional facilities. Those episodes, which involved HIV-infected persons for the most part, resulted in the transmission of TB to health care workers. Core Curriculum, supra note 1, at 15. Several of the workers died.

4. Adherence to the recommended treatment regimen can hardly be taken for granted. The CDC estimates that approximately 25 percent of patients who start treatment for tuberculosis do not complete a recommended regimen within 12 months. Id.

## What Causes TB?

TB is caused by an organism called Mycobacterium tuberculosis or M. tuberculosis. (M. tuberculosis organisms are sometimes called tubercle bacilli.) Infection by M. tuberculosis does not necessarily lead to active TB disease or contagiousness. Only 10 percent of immune-competent persons infected with TB will develop active or contagious TB disease. ^5^ (Of course, the risk of developing active disease is much greater for persons who are immunosuppressed or have human immunodeficiency virus (HIV).) The vast majority of TB-infected persons -- about 90 percent -- will never develop active or infectious disease and will never pose a threat of transmitting TB to others.

5. CDC, Core Curriculum, supra note 1, at 3.

In some cases, infection with M. tuberculosis will lead to active disease within a relatively short time; in others, it may take years before active disease develops, if at all. The progression from infection to disease often depends on individual characteristics, e.g., one's immunologic or general medical status, the recency of one's infection with TB, whether one has a particular medical condition (for instance, cancer or diabetes), and whether one is on an immunosuppressive therapy.

## How Is TB Transmitted?

TB is a communicable disease that is spread primarily by tiny airborne particles (droplet nuclei) expelled into the air by someone with infectious pulmonary or laryngeal TB disease, typically through coughing or sneezing. Depending on ventilation and other factors, these tiny droplets can remain suspended in the air for several hours. Should another person inhale them, he or she may become infected with TB. The probability of transmission will be related to the infectiousness of the person with TB, the environment where the exposure occurred, the duration of the exposure, and the susceptibility of the host.

## Who Is at High Risk for Exposure and Infection?

Although anyone can be exposed to or get TB, some people are at higher risk for both exposure and infection (though exposure does not necessarily result in infection). These higher risk groups include, among others:

- The close contacts of someone who is infectious
- Immigrants from areas where TB is common, such as Asia, Africa, and Latin America ^6^
  6. Of the new TB cases reported in 1993, 30 percent occurred in persons who were born and raised abroad. Core Curriculum, supra note 1, at 14.
- The poor
- The medically underserved
- Racial and ethnic minorities ^7^
  7. Two-thirds of all TB cases in the United States occur in minorities. Id. With respect to the question of TB among racial and ethnic minorities, it should be noted that race is not a causal factor for TB. Listing racial and ethnic minorities here simply reflects the grim fact that many minority group members are poor and medically underserved. It is the lack of proper health care that conduces to the spread of disease among such populations.
- Persons living in congregate settings, such as correctional facilities or residential AOD programs
- Alcoholics and persons who inject drugs ^8^
  8. Though we do not know the precise rate of TB infection among alcoholics and substance abusers, several studies indicate that it is high. One Baltimore study found that over 25 percent of the HIV-seronegative intravenous drug users studied were TB-infected. Neil Graham, et al., Prevalence of tuberculin positivity and skin test anergy in HIV-1-seropositive and seronegative intravenous drug users, JAMA 267:369, 370, 1992. In 1989, 20 to 25 percent of the patients in one New York City methadone maintenance treatment program had positive tuberculin skin test results. Peter A. Selwyn et al., A prospective study of the risk of tuberculosis among intravenous drug users with human immunodeficiency virus infection, N Engl J Med 320:545, 1989. An older but revealing study found that the rate of TB infection among hospitalized drug-dependent persons in New York City was 3,740 per 100,000, as opposed to only 86.7 per 100,000 among the general population. Lee B. Reichman et al., Drug dependence, a possible new risk factor for tuberculosis disease, Archives Internal Med 139:337, 338, 1979. And a 1990 survey of TB-infected persons in three U.S. cities revealed that nearly a quarter had been told that they had "a drinking problem." Jeffrey Glassroth et al., Why tuberculosis is not prevented, Am Rev Respiratory Disease 141:1236, 1990.
- The homeless
- Persons with HIV infection
- Persons who are exposed to infectious TB on the job.

Of those infected with TB, the following run an especially high risk of developing active TB disease:

- Persons with HIV
- Persons whose infection is relatively recent (within the previous 2 years)
- Injection drug users
- Those with a history of inadequately treated TB.

Persons infected with both HIV and TB have the highest known risk factor for developing active TB disease. ^9^ Whereas TB-infected persons who are not HIV-positive run a 10 percent lifetime risk of developing active disease, those with both TB and HIV run a 7 percent to 10 percent chance per year of developing active disease. ^10^

9. Core Curriculum, supra note 1, at 14.

10. Core Curriculum, supra note 1, at 7.

## How Do We Screen for TB Infection?

### Mantoux Tuberculin Skin Test

The preferred method for detecting TB infection -- and the only way to diagnose TB infection before it progresses to active disease -- is a skin test using the Mantoux technique. ^11^ That technique involves the injection of a small amount of purified protein derivative (PPD) just beneath the surface of the skin of the forearm. (The PPD poses no threat of disease or TB infection to the test subject, regardless of the test subject's HIV status.) The result of the test can be read by a trained health care worker within 48 to 72 hours of the time of the injection. Generally, an immune-competent person infected with TB for more than 2 to 10 weeks will produce an immune response to the PPD that manifests itself through the development of an induration at the site of the injection. (An induration is an area of raised, swollen, or hardened skin. ^12^ ) A person not infected with TB will usually produce no induration in response to the PPD. Indurations are measured and recorded in millimeters.

11. Core Curriculum, supra note 1, at 19.

12. The induration or tuberculin reaction is measured and recorded in millimeters. This is true whether or not the reaction is positive or negative, with a completely negative reaction being recorded as "0 mm."

### Reading and Classifying the Tuberculin Reaction

In most cases, a positive reaction to a tuberculin skin test will show that the test subject is TB-infected. Whether a reaction is classified as positive will depend on the size of the induration and the risk factors for infection or disease of the person being tested. Thus, a reaction of 5 mm or more is positive in:

- Persons whose chest x-rays suggest previous TB disease
- Persons who are HIV-positive
- Persons with risk factors for HIV infection
- Close contacts of persons with infectious TB
- Injection drug users whose HIV status is unknown.

A reaction of 10 mm or more is positive in:

- Injection drug users who are HIV seronegative
- Persons with known medical risk factors (other than HIV disease) for developing infectious TB, e.g., diabetes mellitus
- Persons from medically underserved or low income populations, including such high-risk minority groups as Asians, Pacific Islanders, African Americans, Latinos, and Native Americans
- Immigrants from countries where TB is common
- Residents of long-term care facilities
- Health care workers in facilities where TB is present
- The homeless.

All others will be considered to have had a positive reaction to the skin test only if they develop an induration of 15 mm or more. ^13^

13. CDC, Guidelines, supra note 1, at 61; CDC, Core Curriculum, supra note 1, at 21.

### What About Immunosuppressed Individuals?

Between 10 and 25 percent of persons with TB do not react, or react only mildly, to tuberculin skin testing. ^14^ Thus, the fact that someone does not react to the test does not necessarily mean that he or she is not infected. In fact, about one-third of persons with HIV infection -- and 60 percent of those with AIDS -- have a reaction to tuberculin skin testing that in other circumstances would probably not be considered positive. The inability of some immunosuppressed individuals to mount a response to tests such as the tuberculin skin test is known as "anergy." Anergy can be caused by HIV infection, overwhelming miliary or pulmonary TB, severe or febrile illness, measles or other viral infections, Hodgkin's disease, sarcoidosis, live-virus vaccination, and immunosuppressive drugs. Anergy can be detected by the administration (via the Mantoux technique) of at least two additional delayed-type hypersensitivity antigens when testing with PPD. A person whose reaction to any of the three antigens measures 3 mm or more is not anergic.

14. Core Curriculum, supra note 1, at 21.

### Why Is Two-Step Testing Recommended?

Persons who have been infected with TB for many years may lose the ability to mount a positive reaction to tuberculin skin testing. However, a skin test will cause them to have positive reactions to subsequent tests, thus creating the possibility that the reader of the second test will identify the test subject as newly infected. To avoid that confusion, especially for individuals who are to be tested periodically, such as certain AOD employees, programs should employ a two-step testing procedure the first time they screen an individual for TB. Two-step testing calls for the administration of two tuberculin skin tests 1 to 3 weeks apart. If the first test is positive, the person is considered infected. If the first test is negative, a second test will be performed 1 to 3 weeks later. If the second test is positive, the person is probably infected; if it is negative, the person is probably not infected.

### Who Should Be Screened?

High-risk persons should be screened for TB infection. These include:

- Persons with HIV infection
- Persons at risk for HIV
- Close contacts of persons with infectious TB
- Persons with certain medical conditions, such as diabetes mellitus, silicosis, or low body weight
- Persons who inject drugs
- Immigrants from areas where TB is common
- The medically underserved, the poor, and ethnic or racial minorities
- Residents of long-term care facilities
- The homeless.

Substance abuse programs should also screen employees who may be exposed to TB on the job or who would pose a danger to patients and other staff if they were to develop infectious TB. Such employees should be screened upon employment and at intervals dictated by the risk of transmission in the facility (see chapter 6). Screened persons who test positive should be evaluated for active TB disease. If no active disease is present, infected persons at high risk for disease should be considered for preventive therapy.

## Can the Progression From Infection to Active TB Be Prevented?

Persons who test positive for TB infection have a 10 percent lifetime chance of developing active TB disease. Preventive therapy with the anti-TB drug isoniazid or INH may prevent this from occurring. Clinical trials have shown that 6 to 12 months of preventive therapy with INH can reduce the risk of developing active TB disease by 69 to 90 percent. ^15^ The standard preventive treatment regimen consists of 6 months of treatment with INH. ^16^ (HIV-infected persons will be put on 12 months of INH preventive therapy. ^17^ )

15. Core Curriculum, supra note 1, at 36.

16. It is important to rule out TB disease prior to beginning preventive therapy with INH. When INH is used alone to treat TB disease -- which would be the case if a person with active TB disease were placed on INH preventive therapy by mistake -- resistance to INH is likely to develop. Core Curriculum, supra note 1, at 37.

17. Michael D. Iseman, Treatment of multidrug-resistant tuberculosis, N Engl J Med 329:784, 789, 1993; Centers for Disease Control, U.S. Department of Health and Human Services, The use of preventive therapy for tuberculosis infection in the United States: Recommendations of the Advisory Committee for Elimination of Tuberculosis, Morbidity and Mortality Weekly Report 39(RR-8): 9, 11, 1990.

### High-Priority Candidates for Preventive Therapy

Preventive therapy is not routine and is not indicated for all TB-infected persons. In particular, preventive therapy might not be indicated for persons at high risk for adverse reactions to INH, persons who cannot tolerate INH, persons who may have been exposed to a drug-resistant organism, pregnant women (unless they are in a high-risk group), and persons who are unlikely to follow the recommended regimen. The following are high-priority candidates for preventive therapy:

- Persons who are or may be HIV positive
- Close contacts of persons with infectious TB
- Persons whose chest x-ray suggests previous TB but who did not receive adequate treatment
- Persons who inject drugs
- Persons with certain medical conditions
- Persons infected within the preceding 2 years.

Others who should be evaluated for preventive therapy include persons who are under 35 years of age, have reacted to the tuberculin skin test with an induration of 10 or more millimeters, and who are foreign-born, poor, medically underserved, members of a minority group, homeless, or live in long-term care facilities. (Age is significant because those older than 35 years of age are at greater risk of developing INH-related hepatitis.)

### What if a Person Has Been Exposed to a Drug-Resistant Organism?

High-risk patients on INH preventive therapy who are likely to have been exposed to an organism resistant to INH should receive preventive therapy with an alternative antituberculosis drug, e.g., rifampin or RIF. In cases where a patient's strain of M. tuberculosis is resistant to both INH and RIF, preventive therapy becomes more complicated. The CDC recommends that persons who are at high risk for developing TB disease, such as HIV-infected persons who may have been exposed to a multidrug-resistant strain of TB, take at least two antituberculosis drugs to which the infecting organism has shown susceptibility. For persons who are not at high risk for developing TB disease, but who may have been exposed to a multidrug-resistant strain of TB, the CDC recommends either:

1. No preventive therapy but careful monitoring for signs of TB disease, or
2. A regimen of two antituberculosis drugs to which there is demonstrated susceptibility.

In making these recommendations, the CDC cautions that the efficacy of preventive therapy with drugs other than INH and RIF has not been established and that careful monitoring for signs of TB disease is suggested in such cases. An AOD program that is managing a patient who may have been exposed to multidrug-resistant TB should consult with an expert on multidrug-resistant TB for current recommendations regarding preventive therapy. Such experts can be identified through local or State public health departments.

### Do Patients on Preventive Therapy Need To Be Monitored?

Patients on INH preventive therapy must be monitored monthly for adherence to the prescribed regimen and adverse reactions, especially symptoms or signs of hepatitis or neurotoxicity. (Patients should be advised to monitor themselves for the symptoms of hepatitis, which include nausea, vomiting, and loss of appetite.) Because of the importance of adherence to a successful outcome, the responsible clinician will not hesitate to raise adherence issues with his or her patients, count pills, or even order urine tests.

Directly observed preventive therapy will increase the chances of a successful treatment outcome. Directly observed therapy means that someone actually watches the patient take his or her prescribed medication. Although this work is usually performed by local or State public health workers, it can also be done by AOD staff.

With respect to possible adverse reactions, special precautions are recommended for persons who are older than 35 years of age, abuse alcohol, have a history of side-effects with INH, inject drugs, use medications that may contraindicate INH, have chronic liver problems, are pregnant, or have peripheral neuropathy or a condition associated with its development, such as diabetes mellitus.

### Preventive Therapy in AOD Programs

AOD programs that wish to set up a TB preventive therapy program should be aware of the practical difficulties involved in administering preventive therapy. Among other things, programs should bear in mind:

- The importance of proper screening for TB
- The importance of correctly identifying appropriate candidates for preventive therapy
- The need to monitor for adherence and adverse reactions
- The importance of knowing whether the patient has been exposed to a drug- resistant strain of M. tuberculosis, and, if so, the susceptibility pattern of the source case's isolate.

The issues surrounding infection control and TB-related services within AOD programs are discussed in chapter 5.

## Diagnosing Active TB Disease

TB infection and TB disease (or infectious TB) are not the same. Persons who are TB-infected but who do not have TB disease do not pose a danger of transmitting TB to others. Persons with active disease do pose such a danger. The best way, therefore, for a program to prevent the spread of TB within its facilities is to identify, isolate (or remove), and treat (or refer for treatment) patients and staff with active disease.

### Who Should Be Evaluated?

Persons who are suspected of having TB, persons who have a positive reaction to tuberculin skin testing, and persons who present with symptoms that include a prolonged (3 or more weeks) cough, bloody sputum, chest pain, fever, night sweats, easy fatigability, loss of appetite, and weight loss should be evaluated for infectious pulmonary TB. (The index of suspicion will vary depending on the prevalence of TB in the surrounding community, the prevalence of TB in the facility itself, and individual or group risk factors.) An appropriate medical evaluation for TB disease (as opposed to infection) will include a medical history, physical examination, Mantoux tuberculin skin test, chest x-ray, and bacteriologic examination.

### Medical History

A clinician will want to know whether a patient has a history of exposure to TB or a history of TB infection or disease. Where applicable, a clinician will want to know whether a prescribed regimen was adequate and whether it was followed, since inadequate or incomplete treatment may allow TB to recur and may result in drug-resistant forms of the illness. A proper history will inquire into risk factors that may increase the risk for active disease.

### Physical Examination

A physical examination will not rule out or confirm TB. Nevertheless, it may yield valuable information that will help in treating the patient.

### Tuberculin Skin Test

Tuberculin skin testing is discussed earlier in this chapter under "How Do We Screen for TB Infection?" It bears repeating that a negative skin test does not rule out TB, especially for persons who are immunosuppressed.

### Chest X-Rays

Chest x-rays are the traditional method for detecting pulmonary TB disease in a person with a positive PPD and/or such symptoms as a persistent cough, fever, or chills. However, since a person with both HIV infection and active TB disease may have an apparently "normal" film, chest x-rays are not necessarily definitive. Further laboratory examinations of a patient's sputum or other bodily specimens need to be conducted to confirm a diagnosis of TB disease. Chest x-rays can rule out pulmonary TB in a person with a positive skin test reaction but no symptoms of disease.

### Bacteriologic Examination

Persons who are suspected of having pulmonary or laryngeal TB should have a series of three sputum specimens tested for tuberculosis by smear examination and culture. (Sputum is material that is brought up from the lungs; it is different from saliva.) A smear examination involves staining a smear of the patient's sputum with a dye designed to highlight the presence of tubercle bacilli when examined under a microscope. This test can produce a presumptive diagnosis of TB within 24 hours of the specimen's collection.

A smear examination cannot provide a definitive diagnosis of TB disease because the mycobacteria it locates in the sputum may be other than M. tuberculosis. To obtain a definitive diagnosis of TB disease, a laboratory culture of M. tuberculosis must be done. Such cultures are the most accurate method for detecting the presence of TB disease. Cultures can be done on a test subject's sputum, tissues, or bodily fluids. Cultures can be ready within 10 to 14 days of specimen collection. To help prevent transmission of disease, the CDC recommends that, where clinical signs and symptoms indicate the presence of disease, clinicians should not wait for the culture results to begin treatment.

In all cases, the M. tuberculosis isolate should also be tested for drug susceptibility. New tests make it possible to get susceptibility testing results within 5 to 7 days of culture inoculation. Other tests yield results within 2 to 6 weeks.

## Treating Active TB Disease

### What Is the Standard Regimen?

Treating active TB disease can take as little as 6 and as many as 24 months. For treatment to be effective, the TB organisms must be susceptible to the antituberculosis drugs used, the treatment must last long enough to be effective, and the patient must follow the prescribed regimen. The initial treatment regimen will usually consist of drugs, INH, RIF, pyrazinamide, and either ethambutol or streptomycin, and will last 6 months. ^18^ (Single drug regimens are not used because they can lead to the development of drug-resistant strains; multiple drugs reduce the chance of drug-resistance by complementing and reinforcing one another.) Assuming patient adherence and strain susceptibility, fully 95 percent of all immune-competent persons will emerge from treatment free of TB.

18. CDC, Core Curriculum, supra note 1, at 44.

### Directly Observed Therapy (DOT)

Because patient adherence is the single most important factor in the success of treatment (and because about 25 percent of all TB patients do not follow the prescribed treatment regimen), the CDC recommends that treatment be administered by means of directly observed therapy or DOT. (This nonadherence is risky for both the individual concerned and for those in contact with him or her; it can lead to both TB and AOD relapse, the further transmission of TB, and the development of drug resistance.)

DOT means that a health care worker or public health employee will watch the patient to see that he or she takes the prescribed medication. As intrusive and paternalistic as this may seem, DOT has proved to be effective in reducing relapse and drug resistance. Further, it is cost-effective when used with an intermittent regimen, that is, a regimen that requires medication on a less than daily basis. Such regimens are easier to supervise than regimens that require daily medication.

For those programs wishing to employ DOT, the CDC advises that the DOT be carried out at a time and in a location that makes it as convenient as possible for the patient. In any event, all programs providing TB treatment (whether or not they use DOT) should promote adherence by doing the following:

- Developing individualized treatment plans
- Trying to provide culturally and linguistically appropriate outreach staff
- Educating patients about TB, TB treatment, and possible adverse reactions to treatment
- Using incentives
- Easing access to health and social services, where appropriate.

If necessary, the CDC recommends legal action to civilly commit nonadherent patients who are infectious, at risk for becoming infectious, or at risk for becoming drug-resistant.

### Drug-Resistant TB Disease

A patient may acquire drug-resistant TB by developing drug-resistant organisms while being treated for drug-sensitive M. tuberculosis -- either because the drug therapy was inadequate or taken incorrectly -- or through primary infection, i.e., by being infected with a drug-resistant organism. The most common reason for the development of drug resistance is inadequate therapy. The most common drug resistance is to INH, one of the most effective anti-TB drugs.

Drug-resistant TB is treated through an individualized treatment plan based on the drug-susceptibility pattern of a patient's particular strain of M. tuberculosis. Because it can involve a variety of drugs, the treatment regimen for drug-resistant TB can be time-consuming, is often poorly tolerated by the patient, can result in unpleasant side effects, and may have an alarming failure rate.

In the early 1990s, the CDC investigated nine outbreaks of drug-resistant TB disease in hospitals and other institutional settings. The CDC's investigators found widespread multidrug-resistant or MDR TB disease among patients with HIV infection, a mortality rate as high as 72 to 89 percent, and a median interval of only 16 weeks from diagnosis to death. ^19^

19. Centers for Disease Control and Prevention, U.S. Department of Health and Human Services, Initial therapy for tuberculosis in the era of multidrug resistance: Recommendations of the Advisory Council for the Elimination of Tuberculosis, Morbidity and Mortality Weekly Report 42(RR-7): 1-2, 1993.

### Monitoring Treatment for Active Disease

As with preventive therapy, treatment for TB disease must be monitored regularly for both adherence and adverse reactions. Patients should be instructed to look for signs or symptoms of adverse reactions and to report them immediately to health care workers or medical personnel. With respect to side effects, AOD programs should be aware that RIF or rifampin, one of the two key anti-tuberculosis drugs, accelerates the clearance of drugs metabolized by the liver. Thus, patients who are on methadone may require up to a 50 percent increase in their dosage of methadone. Lastly, patients need to be monitored to ensure that treatment is working and that they have not relapsed.

### When May a Patient in Treatment for TB Return to the AOD Program?

To prevent the spread of TB in their facilities, AOD programs must identify, isolate (or remove), and treat (or refer for treatment), all patients and staff with active TB disease. Staff and patients with active disease may not return to the program until it is medically determined that they are not infectious. Fortunately, infectiousness in patients with TB disease declines quickly once effective therapy is implemented. TB-infected patients who have received adequate treatment for 2 to 3 weeks, have responded to the treatment, and have had three consecutive negative smear examinations from sputum taken on 3 separate days are no longer infectious. It will take about 2 months for most infectious TB patients to become noninfectious.