# Appendix F—A Massachusetts Pamphlet on the Connection Between Substance Abuse and Certain Communicable Diseases

This appendix is not available in electronic format. To obtain a hard copy of TIP 18, The Tuberculosis Epidemic: Legal and Ethical Issues for Alcohol and Other Drug Abuse Treatment Providers, contact the National Clearinghouse for Alcohol and Drug Information (NCADI), (800) 729-6686, or access NCADI's web site at http://www.health.org/pubs/catalog/ordering.html. The reference number for this TIP is BKD173.