# Appendix L—Field Reviewers

- Allan D. Ainsworth, Ph.D.
- Program Director
- Wasatch Homeless Health Care Program
- Salt Lake City, Utah

- Kay Anderson, R.N.
- Tuberculosis Controller
- Washington Department of Social and Health Services
- Seattle, Washington

- Vernice Davis Anthony
- Director
- Michigan Department of Public Health
- Lansing, Michigan

- William F. Barry
- Program Coordinator
- Tuberculosis Control Program
- Pennsylvania Department of Health
- Harrisburg, Pennsylvania

- John B. Bass, Jr., M.D.
- American Thoracic Society Director
- Division of Pulmonary and Critical Care Medicine
- College of Medicine
- University of South Alabama
- Mobile, Alabama

- Nancy Bennett
- Administrator
- Special Programs and General Council
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, Illinois

- Linda Bernard, J.D., L.L.M.
- President
- Wayne County Neighborhood Legal Services
- Detroit, Michigan

- Rosa Lee Black, M.S.W.
- Health Program Specialist
- California Department of Health Services
- Tuberculosis Branch
- Sacramento, California

- C. Hope Bolger, R.Ph.
- Medications Consultant
- Office of Substance Abuse Services
- Department of Health, Mental Retardation and Substance Abuse Services
- Richmond, Virginia

- Lynn A. Bosco, M.D., M.P.H.
- Senior Medical Officer
- Agency for Health Care Policy and Research
- Center for Medical Effectiveness Research

- Zenda J. Bowie
- Vice President of Program
- American Lung Association of Georgia, Inc.
- Atlanta, Georgia

- Alex Bowler, M.P.H.
- Tuberculosis Program Coordinator
- Wyoming Department of Health and Social Services
- Cheyenne, Wyoming

- Rosalind Brannigan, M.P.H.
- Vice President
- Drug Strategies
- Washington, D.C.

- Patricia Brougher
- Editor
- Respiratory Care Journal
- Project Manager
- AARC Clinical Practice Guidelines Committee
- Dallas, Texas

- Sylvia Buntin-Simmons, M.S.W., M.P.A., Ph.D.
- Territorial Director
- STD/HIV/TB Program
- Department of Health-Community Health Services
- Virgin Islands Department of Health
- St. Thomas, Virgin Islands

- Jeffrey Caballero
- Project Coordinator
- Association of Asian Pacific Community Health Organizations
- Oakland, California

- A. Martin Cader, M.D.
- Bureau of Tuberculosis Control
- Virginia State Department of Health
- Richmond, Virginia

- John Clark, M.D.
- Chief Medical Officer
- Los Angeles County Sheriff's Department
- Medical Services
- Los Angeles, California

- Karen Connelly, R.N., M.P.H.
- Director
- Office of Public Health Nursing
- Virginia Department of Health
- Richmond, Virginia

- Stella Coughlin
- Assistant Regional Manager
- Department of Public Health
- Bureau of Substance Abuse Services
- Northampton, Massachusetts

- Michael Couty
- Director
- Division of Alcohol and Drug Abuse
- Missouri Department of Mental Health
- Jefferson City, Missouri

- George DiFerdinando, M.D., M.P.H.
- Medical Director
- Division of Tuberculosis Control
- New York State Department of Health
- Association of State and Territorial Health Officials
- Albany, New York

- Christina Dye
- Program Representative
- Office of Substance Abuse
- Arizona Department of Health Services
- Phoenix, Arizona

- Ronald D. Eckoff, M.D., M.P.H.
- Medical Director
- Division of Substance Abuse and Health Promotion
- State of Iowa Department of Public Health
- Des Moines, Iowa

- Miguel A. Escobedo, M.D.
- Medical Director
- Communicable Disease Services
- El Paso City/County Health District
- El Paso, Texas

- Sue C. Etkind
- Director
- Tuberculosis Program
- Massachusetts Department of Public Health
- Jamaica Plain, Massachusetts

- Charles P. Felton, M.D.
- Chief
- Division of Pulmonary Medicine
- Harlem Hospital Center
- New York, New York

- Susan Forlenza, M.D.
- Chief
- Division of Infectious Disease
- Nassau County Medical Center
- East Meadows, New York

- Clifford G. Freund, M.P.H.
- Director
- Communicable Disease Control Service
- New Jersey State Department of Health
- Trenton, New Jersey

- Thomas M. Fritz
- Director
- Delaware Division of Alcoholism, Drug Abuse and Mental Health
- New Castle, Delaware

- James Gorman, J.D., C.S.W.
- Clinical Supervisor
- National Council on Alcoholism
- Lansing Regional Area, Inc.
- Lansing, Michigan

- Vicky Groskiwsky
- Program Manager
- Division of Substance Abuse
- New Mexico Department of Health
- Santa Fe, New Mexico

- James L. Hadler, M.D., M.P.H.
- State Epidemiologist
- Division of Infectious Disease Surveillance and Control
- Connecticut Department of Public Health Addiction Service
- Hartford, Connecticut

- Kathryn B. Hall, M.B.A.
- Substance Abuse Program Director
- Virginia Beach Community Services Board
- Virginia Beach, Virginia

- J. M. Holcombe, M.P.A.
- Program Director
- Tuberculosis Program
- Mississippi State Department of Health
- Jackson, Mississippi

- Philip Hopewell, M.D.
- Chief
- Division of Pulmonary and Critical Care
- San Francisco General Hospital
- San Francisco, California

- Joseph P. Iser, M.D.
- Director
- Office of Pacific Health
- U.S. Public Health Service
- San Francisco, California

- Michael Kelley, M.D., M.P.H.
- Chief
- Bureau of Communicable Disease Control
- Texas Department of Health
- Austin, Texas

- Karen Kroc
- Assistant Director
- Infection Control and Environmental Safety
- American Hospital Association
- Chicago, Illinois

- R. Dee Legako, M.D.
- American Academy of Family Physicians
- Edmond, Oklahoma

- John N. Lozier
- Executive Director
- National Health Care for the Homeless Council
- Nashville, Tennessee

- Anna R. McClain, R.N.
- National Black Nurses Association
- Silver Spring, Maryland

- Francis A. McCorry, Ph.D.
- Director
- HIV Services
- New York State Office of Alcoholism and Substance Abuse Services
- New York, New York

- David R. McDuff, M.D.
- Associate Professor of Psychiatry
- University of Maryland School of Medicine
- Baltimore, Maryland

- Marlene McMullen-Pelsor
- Director
- Office of Substance Abuse Prevention
- Augusta, Maine

- Jacqueline Messite, M.D.
- Executive Director
- Public Health
- New York Academy of Medicine
- New York, New York

- John R. Miles, M.P.A.
- Assistant Chief
- Substance Abuse Activities
- Programs Operations Branch
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- James J. O'Connell, M.D.
- Director
- Boston Health Care for the Homeless Program
- Boston, Massachusetts

- Andrew O'Donovan
- Commissioner
- Kansas Alcohol and Drug Abuse Services
- Topeka, Kansas

- Roger H. Peters, Ph.D.
- Associate Professor
- Department of Mental Health, Law and Policy
- University of South Florida
- Tampa, Florida

- O'Neill Pollingue
- Director
- Division of Substance Abuse Services
- Alabama Department of Mental Health and Mental Retardation
- Montgomery, Alabama

- John Poundstone, M.D., M.P.H.
- Commissioner of Health
- Lexington Fayette County Health Department
- American Association of Public Health Physicians
- Lexington, Kentucky

- Deborah J. Powers
- IDU/AIDS Treatment Specialist
- Department of Health and Social Services
- Wisconsin Bureau of Substance Abuse Services
- Madison, Wisconsin

- Norbet P. Rapoza, Ph.D.
- Director
- Immunology and Infectious Diseases
- American Medical Association
- Division of Drugs
- Chicago, Illinois

- Marcia Richards, R.N., B.S.
- Long Term Care Nurse Specialist
- American Health Care Association
- Washington, D.C.

- Gary A. Roselle, M.D.
- Program Director for Infectious Disease
- Department of Veterans Affairs
- Medical Center
- University of Cincinnati College of Medicine
- Cincinnati, Ohio

- Patricia Salomon, M.D.
- Chief Medical Officer
- Bureau of Primary Health Care
- Health Resources and Services Administration
- U.S. Public Health Service
- Bethesda, Maryland

- Roger Schilling, M.P.H.
- Program Manager
- Georgia Tuberculosis Control Program
- Northwest Georgia Regional Hospital
- Rome, Georgia

- Walter F. Schlech, M.D.
- ACC 5014
- Victoria General Hospital
- Halifax, Nova Scotia, Canada

- William R. Schmidt, M.P.H., PA-C
- Division Director
- Division of Environmental Health and Epidemiology
- Missouri Department of Health
- Jefferson City, Missouri

- Kristen Schweight
- Tuberculosis Project Coordinator
- Office of Communicable Disease Prevention and Control
- South Dakota State Department of Health
- Pierre, South Dakota

- Beverly Sheets, R.N., B.G.S.
- Public Health Nurse Consultant
- Tuberculosis Program
- Indiana State Department of Health
- Indianapolis, Indiana

- Kevin Sherin, M.D.
- Executive Director
- DuPage County Health Department
- Wheaton, Illinois

- Gene D. Simmons, M.P.H.
- Program Manager
- Tuberculosis Control Program
- Kentucky Department for Health Services
- Frankfort, Kentucky

- Dixie E. Snider, Jr., M.D., M.P.H.
- Associate Director for Science
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Lois Snyder, J.D.
- Ethics and Health Policy Counsel
- American College of Physicians
- Philadelphia, Pennsylvania

- Jeffrey R. Starke, M.D.
- Assistant Professor of Pediatrics
- Department of Pediatrics
- Baylor College of Medicine
- Texas Children's Hospital
- Houston, Texas

- William W. Stead, M.D.
- Director
- Tuberculosis Program
- Arkansas Department of Health
- Little Rock, Arkansas

- Harry A. Stern
- Associate Director for TB/HIV Activities
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Rita Sullivan, Ph.D.
- Director
- OnTrack, Inc.
- Comprehensive Counseling and Human Services
- Medford, Oregon

- Bruce Tempest, M.D.
- Tuberculosis Control Officer
- Navajo Indian Health Service
- Gallup Indian Medical Center
- Gallup, New Mexico

- Jon Tillinghest, M.D., M.P.H.
- Tuberculosis Control Officer
- Communicable Disease Division
- Oklahoma State Department of Health
- Oklahoma City, Oklahoma

- Basil Vareldzis, M.D., M.P.H.
- Senior Technical Advisor for TB/HIV
- U.S. Agency for International Development
- Washington, D.C.

- Wayne A. Wallace, B.A., R.R.T.
- AARC Ad Hoc Committee on Infection Control
- Kodiak, Alaska

- Valerie Ann Welsh
- Senior Health Policy Analyst
- Office of Health Planning and Evaluation
- Office of the Assistant Secretary for Health
- Department of Health and Human Services
- Washington, D.C.

- Melanie Whittier
- Administrator
- Special Programs and General Council
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, Illinois

- Elaine Wilson
- Chief
- Alcohol and Drug Abuse Division
- Honolulu, Hawaii

- Gail L. Woods, M.D.
- College of American Pathologists
- Professor of Pathology
- University of Texas Medical Branch
- Department of Pathology
- Galveston, Texas

- Thomas T. Yoshikawa, M.D.
- Office of Geriatrics and Extended Care
- Assistant Chief Medical Director for Geriatric Extended Care
- Department of Veterans' Affairs
- American Geriatrics Society
- Washington, D.C.

- John K. Zachariah
- Chief Probation Officer
- Cuyahoga County Juvenile Court
- Cleveland, Ohio