# Appendix K—Federal Resource Panel

- Duiona R. Baker, M.P.H.
- Special Assistant for Alcohol and Other Drug Abuse and Infectious Disease Prevention
- Quality Assurance and Evaluation Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration

- Michael J. Brennan, Ph.D.
- Chief, Laboratory of Mycobacteria
- Division of Bacterial Products
- Center for Biologics Evaluation and Research
- Food and Drug Administration

- James F. Callahan, D.P.A.
- Executive Vice President and CEO
- American Society of Addiction Medicine

- Diane M. Canova, J.D.
- Executive Director
- Therapeutic Communities of America
- Arlington, Virginia

- Michele Carter, Ph.D.
- Bioethics Consultant
- Substance Abuse and Mental Health Services Administration

- Scott Clay
- Manager
- Infectious Disease National Programs
- American Lung Association

- Lenora S. Colbert
- Vice President and Director
- Local 1199
- Occupational Safety and Health Department
- New York, New York

- Al DeMaria, M.D.
- Associate Commissioner and Public Health State Epidemiologist
- Massachusetts Department of Public Health

- Melanie Duckworth, M.S.W.
- Public Health Analyst
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention

- Sue C. Etkind
- Director, Tuberculosis Program
- Massachusetts Department of Public Health

- June S. Ewing, M.S.
- Review Policy Analyst
- Office of Extramural Programs
- Substance Abuse and Mental Health Services Administration

- John D. Foulds, Ph.D.
- Tuberculosis Program Officer
- Respiratory Diseases Branch
- Division of Microbiology and Infectious Diseases
- National Institute of Allergy and Infectious Diseases
- National Institutes of Health

- Paul A. Gaist, M.P.H.
- Senior Advisor
- Office of AIDS Research
- U.S. Department of Health and Human Services
- National Institutes of Health

- Joel Goldstein, Ph.D.
- Deputy Director
- Office of Extramural Programs
- Substance Abuse and Mental Health Services Administration
- Harry W. Haverkos, M.D.

- Acting Director
- Division of Clinical Research
- National Institute on Drug Abuse
- National Institutes of Health

- Edward T. Morgan
- Acting Chief
- Human Resources Development
- Office for Scientific Analysis and Evaluation
- Center for Substance Abuse Treatment

- David H. Mulligan
- Commissioner
- Massachusetts Department of Public Health
- Executive Office of Health and Human Services

- John W. Poundstone, M.D., M.P.H.
- Commissioner of Health
- American Association of Public Health Physicians
- Lexington Fayette County Health Department
- Lexington, Kentucky

- Gary A. Roselle, M.D.
- Program Director for Infectious Disease
- Department of Veterans Affairs Medical Center
- University of Cincinnati College of Medicine

- Margaret Salinger, M.S.N., R.N., C.A.R.N.
- Head Nurse/Supervisor
- Substance Abuse Treatment Unit
- National Nurses Society on Addictions
- Coatesville Veterans Medical Center
- Audubon, Pennsylvania

- John J. Seggerson
- Chief of the Programs Services Branch
- Division of Tuberculosis Elimination
- Centers for Disease Control and Prevention

- Donald Storms, C.A.C, C.D.A.C.
- Chair, HIV/AIDS and Substance Abuse Committee
- National Association of Alcoholism and Drug Abuse Counselors

- Alan I. Trachtenberg, M.D., M.P.H.
- Medical Officer
- Science Policy and Analysis Branch
- National Institute on Drug Abuse

- Sylvia Trent-Adams, R.N.
- Public Health Analyst
- Division of Programs for Special Populations
- Bureau of Primary Health Care
- Health Resources and Services Administration

- Karen S. Wagner, J.D.
- Office of the General Counsel

- Department of Health and Human Services
- Brian M. Willis, J.D., M.P.H.
- Attorney Advisor
- Office of the General Counsel
- Centers for Disease Control and Prevention

- Edward L. Zuroweste, M.D.
- Medical Director
- Keystone Migrant Health