# Appendix J—CDC: Essential Components of a TB Prevention and Control Program; and Screening for TB and TB Infection in High-Risk Populations

Mordibity and Mortality Weekly Report Recommendations and Reports: September 8, 1995/Vol. 44/No. RR-11 You must use Adobe Acrobat to view this document. To download the Acrobat Reader, go to Adobe's Web Site and follow the instructions.