# Appendix A—Bibliography

## Medical Literature

American Thoracic Society. Control of tuberculosis in the United States: An official joint statement of the American Thoracic Society, the American Academy of Pediatrics, the Centers for Disease Control and the Infectious Disease Society of America. American Review of Respiratory Disease. 1992;146:1623-1633.
American Thoracic Society and the Centers for Disease Control. Diagnostic Standards and Classification of Tuberculosis. American Review of Respiratory Disease. 1990;142:725.
Bellin, E.; Fletcher D.; and Safyer, S. Abnormal chest x-rays in intravenous drug users: Implications for tuberculosis screening programs. American Journal of Public Health. 1993;83(5):698-700. [pmid: 8387246].
Centers for Disease Control. Screening for tuberculosis and tuberculous infection in high-risk populations and the use of preventive therapy for tuberculous infection in the United States: Recommendations of the Advisory Committee for the Elimination of Tuberculosis. Morbidity and Mortality Weekly Report. 1990;39(RR-8).
Centers for Disease Control. Transmission of multidrug-resistant tuberculosis from an HIV-positive client in a residential substance-abuse treatment facility—Michigan. Morbidity and Mortality Weekly Report. 1991;40(8) 129-131.
Centers for Disease Control. National action plan to combat multidrug-resistant tuberculosis; Meeting the challenge of multidrug-resistant tuberculosis: summary of a conference; and Management of persons exposed to multidrug-resistant tuberculosis. Morbidity and Mortality Weekly Report. 1992;41(RR-11):1-71.
Centers for Disease Control. What Drug Treatment Centers Can Do To Prevent Tuberculosis. Pamphlet. Atlanta, GA: U.S. Department of Health and Human Services, n.d.
Centers for Disease Control and Prevention. Initial therapy for tuberculosis in the era of multidrug resistance: Recommendations of the Advisory Council for the Elimination of Tuberculosis. Morbidity and Mortality Weekly Report. 1993;42(RR-7):1-8.
Centers for Disease Control and American Thoracic Society. Core Curriculum on Tuberculosis. 1991;2d ed. New York: American Thoracic Society.
Iseman, M.D. Treatment of multidrug-resistant tuberculosis. New England Journal of Medicine. 1993;329 (11):784-791.
Mahmoudi, A., and Iseman, M.D. Pitfalls in the care of patients with tuberculosis: Common errors and their association with the acquisition of drug resistance. Journal of the American Medical Association. 1993;270 (1):65-68.
Selwyn, P.A.; Sckell, B.B.; Alcabes, P.; Friedland, G.H.; Klein, R.S.; and Schoenbaum, E.E. High risk of active tuberculosis in HIV-infected drug users with cutaneous anergy. Journal of the American Medical Association. 1992;268(4):504-509, July 22B29.

## CDC and OSHA Guidelines for Preventing TB Transmission in the Workplace

Centers for Disease Control. Guidelines for preventing the transmission of tuberculosis in health-care settings, with special focus on HIV-related issues. Morbidity and Mortality Weekly Report. 1990;39(RR-17):1-29.
Centers for Disease Control. Draft Guidelines for Preventing the Transmission of Tuberculosis in Health-Care Facilities. 2d ed. Federal Register 58(52):810. 1993.
Occupational Safety and Health Administration, United States Department of Labor. Enforcement Policy and Procedures for Occupational Exposure to Tuberculosis. October 8, 1993. (Amending 29 C.F.R. § 1910.134.).

## Legal Materials

Americans With Disabilities Act, 42 U.S.C. §§ 12101 et seq.
Annas, G.J. Control of tuberculosis—The law and the public's health. New England Journal of Medicine. 1993;328:585.
Bayer, R,; Dubler, N.N.; and Landesman, S. The dual epidemics of tuberculosis and AIDS: Ethical and policy issues in screening and treatment. American Journal of Public Health. 1993;83(5):649-654. [pmid: 8484443].
Centers for Disease Control and Prevention. Tuberculosis Control Laws—United States, 1993: Recommendations of the Advisory Council for the Elimination of Tuberculosis (ACET). Morbidity and Mortality Weekly Report. 1993;42(RR-15).
Gostin,L.O. Controlling the re-emergent tuberculosis epidemic: A 50-State survey of TB statutes and proposals for reform. Journal of the American Medical Association. 1993;269:255-261.
Regulations on the Confidentiality of Alcohol and Drug Abuse Patient Records, 42 C.F.R. Part 2, 1989.
The Rehabilitation Act of 1973, 29 U.S.C. §§ 706 (Definitions), 794 (Section 504 of the Act).