# Consensus Panel

Chair
- Gerald L. Vigdal, M.S.W., B.C.D.
- Director, Office of Drug Programs
- Wisconsin Department of Corrections
- Madison, Wisconsin

Facilitators
- Michael J. Stringer
- Chief, Division of Special Programs
- Department of Alcohol and Drug Addiction Services
- State of Ohio
- Columbus, Ohio
- Patricia L. Watson, M.Ed.
- President
- Corrections Alternatives and Concepts
- Smyrna, Delaware
- William R. Woodward, M.P.A.
- Director, Division of Criminal Justice
- Colorado Department of Public Safety
- Denver, Colorado

Workgroup Members
- Catherine E. Bartels, M.Ed., C.C.D.C. III
- Director of Substance Abuse Programs
- South Dakota Department of Corrections
- Pierre, South Dakota
- David Brenna, M.S.
- Special Projects Manager, Department of Social and Health Services
- Division of Alcohol and Substance Abuse
- State of Washington
- Olympia, Washington
- Margaret K. Brooks, J.D.
- Consultant
- Montclair, New Jersey
- John A. Carver, J.D.
- Director
- District of Columbia Pretrial Services Agency
- Washington, D.C.
- Frederick R. Chavaria, Ph.D.
- United States Probation and Parole Officer
- Substance Abuse and Contractor Specialist
- United States Probation Office
- Northern District of California
- San Francisco, California
- John H. Clark, Junior, M.D., M.P.H., C.C.H.P.
- Chief Medical Officer
- Office of the Sheriff
- Los Angeles County Sheriff's Department
- Los Angeles, California
- Michael M. Gimbel
- Director
- Baltimore County Office of Substance Abuse
- Towson, Maryland
- Genita Johnson, M.D., M.P.H.
- Consultant
- Medford, Massachusetts
- Nicholas Pastore
- Chief of Police
- New Haven Department of Police Service
- New Haven, Connecticut
- William H. Pimentel, M.A.
- Assistant Director
- Rhode Island Department of Substance Abuse
- Rhode Island Medical Center
- Cranston, Rhode Island
- The Honorable Dalton A. Roberson, Sr.
- Chief Judge
- Detroit Recorder's Court
- Detroit, Michigan
- Rose Soo Hoo, M.S.W., M.B.A.
- Administrator, King County North Rehabilitation Facility
- Division of Alcohol and Substance Abuse Services
- Seattle, Washington
- Cheryl Clark Walker, M.P.A.
- Program Specialist, Substance Abuse Program Section
- Michigan Department of Corrections
- Lansing, Michigan