# Chapter 9—Evaluation ^16^ 1. This chapter was written by Michael L. Prendergast, Ph.D., Drug Abuse Research Center, University of California at Los Angeles.

Alcohol and other drug (AOD) treatment programs for offenders are designed to achieve certain goals, such as reduced AOD use, decreased criminal activity, and increased employment. Programs may also attempt to improve psychological status or family relationships, or to reduce emergency room use. Evaluation can be used to assess the attainment of these goals. Evaluation can also help identify problems with implementing programs and program components that are ineffective or need modification. In this chapter, evaluation refers to the use of research methods to measure the extent to which a program achieves its goals or produces certain other effects.

Evaluation studies are used to assess programs and examine their effectiveness before large amounts of time, money, and other resources are invested. (Chapter 2 reviews several studies of the effectiveness of AOD treatment in the criminal justice system.) Programs that prove to be ineffective or marginally effective can be examined more closely and modified to enhance their effectiveness. Even a highly successful program can benefit from an examination of the components that contribute to positive outcomes in order to eliminate the components that have no impact, to document a theoretical base, and to provide information for use in replication (Rossi, 1987).

## Purpose of Evaluation

Program evaluations serve a practical rather than a theoretical purpose -- to collect reliable evidence that can be used to persuade key decisionmakers to commit financial and other resources. Those decisionmakers might include legislators, agency administrators, and foundation directors. Thus, program evaluation provides one source of input for policymakers to use in the decision process. It is important to note that a direct relationship exists between the persuasive power of requests for funding based on program effectiveness and the strength and integrity of the program's evaluation study. A program with strong evaluation results is likely to receive a better hearing and to have a higher chance of continued or increased funding than a program with no outcome results. However, reality has shown that policymakers come to decisions based on the best available evidence, which in some cases may be quite limited and poorly founded.

Evaluations examine program implementation and operation (process evaluation) and program outcomes (outcomes evaluation). This chapter addresses process evaluation to a limited degree; it primarily focuses on selected issues related to evaluating the outcomes of criminal justice treatment programs, and it includes summaries of the results of several outcomes studies.

It is important to note that programs should be designed so that an evaluation component is built in from the outset and is an ongoing aspect of the program's operation. The types of data gathered and the manner in which they are stored should facilitate the evaluation function. When new program elements are introduced, ways to evaluate their effectiveness should play a strong role in their implementation.

A separate Treatment Improvement Protocol (TIP) in this series, TIP 14: Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment, describes the evaluation process and addresses the many variables that should be addressed in well-designed studies.

## Process Evaluation

Process evaluation is useful in examining the implementation procedures and operation of a treatment program in comparison with the program's stated intent. Process evaluation can be used to determine whether subjects actually received the intervention as it was intended to be delivered. Process evaluation also can be used to measure the intensity and duration of the services provided. Unless the evaluation describes what happens during treatment, program strengths will not be described and changes in program design will not be made.

Numerous treatment efforts have been ineffectual, misunderstood, or misinterpreted because what was actually implemented was not what was described in the original program design. Process evaluation can be used to assess whether the program that was originally designed is the program that is being tested. In addition, process evaluation can help interpret the results of an outcome evaluation. Process evaluation provides an assessment of the program's strengths and weaknesses and can indicate ways in which a program can be improved, serving as a management tool for program development.

Process evaluation is useful in examining the implementation procedures and operation of a treatment program in comparison with the program's stated intent. Process evaluation can be used to determine whether subjects actually received the intervention as it was intended to be delivered.

## Outcomes Evaluation

Outcomes evaluation is designed to determine the effectiveness of an intervention as compared with a control (no treatment) group, an alternative intervention, or a standard intervention. It measures and assesses a program's effect; that is, the ability of a program to produce changes of the specified type and desired direction in the people who are exposed to it.

Ideally, the evaluation should be conducted by an external person or group to avoid bias in data collection and analysis. However, many institutions and programs conduct their own evaluations and such evaluations can be very useful.

Program evaluation can provide answers to a number of questions. Did the treatment group show significant change in relation to the comparison group, and can that change be attributed to the intervention? How well does the program work in real-world settings? With which subgroups does it work? What kinds of effects can be expected from the program and at what magnitude? What are the essential ingredients of the program? Obtaining answers to each of these questions requires changing the research strategy. Thus, a program evaluator must have a clear idea about the purpose of the evaluation to develop the appropriate evaluation design.

## Evaluation Issues

A number of problems can occur when implementing outcomes evaluation studies. These problems can call the validity of the evaluation results into question. The occurrence of one or more of the following problems makes it difficult to determine what is being evaluated, whether the results are valid, or whether the results can be applied to the intended population (Dennis, 1993):

- Variations in the delivery of treatment such as unplanned alterations in the amount of counseling received by clients.
- Contamination of the evaluation design; for instance, knowledge or resources that are intended only for the treatment group also are received by the comparison group.
- Too few subjects are included in the study, a fact that may not be known until after the evaluation has begun.
- Compromise of the random assignment procedure; for example, parole officers should not assign clients to the randomly selected group.
- Changes in the environment within which the evaluation takes place; for instance, new State regulations may require modification in the treatment protocol.
- Changes that occur in the intervention over time such as staff turnover.

The presence of any of these problems can lead to questions about the validity of the evaluation results. To the extent possible, the program evaluator should take steps before the study commences to reduce the likelihood that these problems will occur. For instance, written protocols and careful documentation make for greater uniformity and delivery of services. Or, a pilot study to examine the flow of clients with the targeted characteristics through a probation department could ensure the availability of an adequate number of study subjects. The implementation also should be carefully monitored to preserve the integrity of the research design. If deviations occur, they should be documented and reported in the final study report.

### Sample Size

One issue of particular importance to assessing the effectiveness of treatment programs is sample size. The smaller the sample size, the lower the probability of detecting statistically significant treatment effects. This aspect of the research design, known as power analysis, is often overlooked, but it is important because program evaluations with sample sizes that are not large enough to detect treatment effects can waste resources and may lead to abandoning otherwise promising treatment approaches.

The "nothing works" doctrine in the criminal justice field is partly attributable to research studies with small samples that failed to give rehabilitation programs a chance to prove themselves. To correct this problem, the evaluator should determine a sample size that is large enough to show whether the intervention makes a difference in the population and to conclude whether the treatment program did produce an effect. The technical procedure for doing this is beyond the scope of this chapter but can be found in a number of standard texts (Cohen, 1977; Lipsey, 1990).

Successful program implementation and management depends on more than a good design and an adequate number of subjects. It also relies on the cooperation of staff and others involved in the intervention. This cooperation can be expected in a research environment. But in "real-world" settings like prisons, jails, probation departments, and community treatment programs, the intervention can place demands on people that they initially may be unwilling to assume. If staff members are not convinced of the need for the study, they can actively undermine the evaluation procedures.

An evaluator may use a number of strategies to gain and maintain the cooperation of program staff (Dennis, 1993), including

- Explaining to staff the purpose of the study and how the results will be used
- Sharing the draft instruments and the study procedures with staff for their review and feedback
- Taking staff concerns about the study seriously and making accommodations that do not compromise the study's integrity
- Providing staff with periodic feedback on the study's progress and preliminary findings
- Being aware of the time schedule and program deadlines and attempting to minimize conflicts between program activities and study procedures.

### Research Followup

Similar considerations apply to gaining a subject's cooperation. Methods must be developed to reduce study attrition, from which every study suffers. The longer the study, the greater the number of subjects who drop out. Attrition can bias the results and, in the worst case, defeat the study.

Researchers have developed a number of techniques (Dennis, 1993) that can be used to reduce subject attrition:

- Strengthening the client's study commitment by explaining the purpose and how the results will be used
- Paying subjects (or providing other incentives) for keeping appointments, completing interviews, and complying with other study requirements
- Collecting client locator information, including other people who will know the whereabouts of the client at the time of followup, and staying in contact with clients via phone calls or postcards
- Using information from official records and agencies to locate hard-to-find clients for followup interviews
- Using outreach workers who are familiar with the client's community to help locate clients for followup
- Including measures in the study design that make use of program or criminal justice records so that data will be available for all study clients regardless of attrition.

### Outcomes Measures

A variety of measures have been used to assess the effectiveness and treatment outcomes for AOD-involved offenders. These outcome measures include changes in

- Drug use
- Criminal activity
- Personality traits
- Attitudes
- Vocational skills
- Employment
- Institutional adjustment
- Family relationships
- Involvement in social activities.

The specific measures selected should include behaviors specified in program goals and objectives. The treatment program designed to reduce substance use, decrease criminal involvement, improve self-concept, and increase job skills must include an evaluation designed to collect data on each of these variables.

The smaller the sample size, the lower the probability of detecting statistically significant treatment effects. This aspect of the research design, known as power analysis, is often overlooked, but it is important because program evaluations with sample sizes that are not large enough to detect treatment effects can waste resources and may lead to abandoning otherwise promising treatment approaches.

Outcomes measures can cover a wide variety of psychological and social behaviors, but the primary purpose of most treatment programs for offenders is to reduce drug use and the criminal activity associated with it. Regardless of the positive benefits programs may produce, criminal justice drug treatment programs that are unable to bring about significant reductions in drug use and recidivism cannot be regarded as effective. Thus, measures that focus on relapse and recidivism are commonly used as indicators of program effectiveness in criminal justice settings. Neither relapse nor recidivism are simple behavioral measures. Both can be used to refer to a variety of behaviors and can be defined in a variety of ways.

#### Relapse

Relapse is not clinically regarded as a treatment failure, but as an indication that the treatment plan should be changed to address the cause or circumstances associated with the relapse. Some clinicians distinguish between the degrees of relapse -- from a single "slip," to sporadic use or a return to addiction. For research purposes, however, relapse often is defined as the single use of a specified drug during a given period of time. Various relapse studies have reported that more than 50 percent of people treated for alcohol or other drug dependence relapse within a year after a single treatment episode, and that that percentage increases with longer followup periods (Maddux and Desmond, 1986). As a result, treatment success can be measured as a reduction in the relapse rate when compared with the relapse rate of an untreated group or a group that received a different treatment.

Drug use can be measured either by urine tests or by self-report. Some studies rely on self-reported drug use only, while others (Wish and Gropper, 1990) use validated urine test results. Urine test results can be abstracted from client records at little cost for some treatment evaluations. For followup studies, clients can be asked to provide urine specimens following the interview and the cost of testing can be factored into the evaluation budget. The evaluator should carefully consider the drugs that are of greatest relevance to the objectives of the program being studied. A potential problem is that subjects may refuse to provide urine specimens. If specimens are not collected from a large number of clients, the study's purpose can be undermined. However, inadequate collection has not proven to be a major problem. For instance, in the Drug Use Forecasting program, 80 percent or more of those interviewed in jails agreed to provide a urine sample (National Institute of Justice, 1992).

Relapse is not clinically regarded as a treatment failure, but as an indication that the treatment plan should be changed to address the cause or circumstances associated with the relapse.

Although self-report results underestimate drug use (Mieczkowski, 1990; Rouse et al., 1985; Wolber et al., 1990), self-reports provide information about use patterns that cannot be obtained from drug testing. Thus, through self-reports, the evaluator can obtain reasonably reliable data on quantity and frequency of use, method of administration, circumstances of use, and reasons for use. These measures may be more useful for assessing the impact of a treatment program than merely determining whether the person tested positive at the 6-month followup interview.

#### Recidivism

Waldo and Griswold (1979) use the following definition of recidivism: "an offense committed by a person who has previously been convicted or adjudicated for an offense." This definition focuses on the behavior rather than "tendencies" or "proneness" and includes offenses that appear in official records and those that do not. In studies of treatment effectiveness, recidivism data usually are obtained from official criminal justice records. In addition, studies also may ask subjects about their criminal behavior during the followup period (Weis, 1986). But even if evaluators decide to rely on official records as the measure of recidivism, they must decide which level of contact with the criminal justice system will be used to determine recidivism. Should the measure of recidivism be rearrest, reconviction, reincarceration, or technical violations of probation or parole?

Although there may be theoretical or methodological reasons for selecting one measure or a combination of measures, in practice, the choice will depend on the purpose of the study, the access the evaluator has to official records, and budget constraints. In addition to recidivism, official records often permit the evaluator to select other measures of the program's impact on criminal behavior, such as the number of rearrests or technical violations during the followup period, the types and severity of the offense(s) committed, the time to rearrest from program discharge, the length of any sentence imposed, and the annual rate of arrest, controlling for time on the street.

The interpretation of recidivism rates is not always straightforward. Although most criminal justice outcome studies use recidivism from official records, researchers have noted (Turner et al., 1992) that "recidivism is actually a product of the offender's underlying criminality and the System's ability to detect that criminality and act on it (e.g., arrest probability)." For example, offenders in a community treatment program are committing fewer crimes than those not in treatment, but the increased supervision and surveillance associated with the treatment program increases the probability that their crimes and technical violations will be detected. Thus, even though the actual rate of the criminal behavior for the treatment group may be lower than for the comparison group, the treatment group's "official" behavior may be the same or worse than that of the comparison group. Collecting self-report data would be one way of clarifying the relationship between the offender's criminal behavior and the criminal justice system's ability to respond to the behavior.

If evaluators decide to rely on official records as the measure of recidivism, they must decide which level of contact with the criminal justice system will be used to determine recidivism. Should the measure of recidivism be rearrest, reconviction, reincarceration, or technical violations of probation or parole?

## Endnote