# Chapter 5—The AOD Abuse Treatment System ^2^ 1. David Brenna, M.S., from the Department of Social and Health Services in the State of Washington, contributed to this chapter.

This chapter presents an overview of the alcohol and other drug (AOD) abuse treatment system. The AOD system is complicated because Federal, State, and county sources may provide funding and may have separate oversight and accountability requirements. (There also are private treatment programs, but they are not covered in this chapter.) Treatment approaches and services presented here and used in various parts of the country incorporate a variety of settings and modalities and include detoxification; inpatient, outpatient, intensive outpatient, and residential treatment; methadone maintenance; and self-help groups. Individual, group, and family interventions are used as part of the intervention repertoire to change specific behaviors such as AOD abuse. In addition, prevention and educational interventions are used in communities across the United States with the goal of decreasing AOD abuse.

## The Role of State AOD Agencies

Knowledge of the AOD abuse treatment system is needed to effectively develop intervention programs within the criminal justice system. Current treatment can be better understood in its historical context. AOD treatment emerged from the mental health system during the 1950s. Many AOD treatment professionals remained concerned with protecting the independent treatment service structure. The battle to establish independent AOD treatment services was difficult. Many in the field developed a strong sense of keeping perceived "outsiders" such as physicians and hospitals from becoming involved in treatment and related issues. Professional associations were formed; and, as Federal and State AOD treatment funding became available, State AOD treatment organizations developed. Today, in each State a single State AOD agency, led by a State AOD director, not only administers Federal block grant funds and sets treatment standards, but is also the hub for organized public programs. As criminal justice systems develop and adopt treatment programming, an understanding of the critical role State AOD agencies play in relation to publicly funded AOD programs is essential.

State AOD agencies provide technical assistance (TA) in both treatment program management and service delivery. State agencies are mandated by law to establish regulations for certifying treatment providers and licensing programs. State agencies also routinely monitor certified providers and licensed programs to ensure that high-quality services are delivered. While most States do not mandate licensure for correctional treatment programs, it is recommended that justice system treatment programs pursue State approval. States may need to develop specific licensing criteria for correctional treatment programs. Pursuing State approval for justice system programs can, at a minimum, provide the impetus to establish a working relationship with the AOD treatment community, gain recognition for the justice system program as a treatment provider, and educate State agencies as well as treatment providers about the special needs of offenders.

State licensing of justice system AOD treatment can, at a minimum, provide the impetus to establish a working relationship with the AOD treatment community, gain recognition for the justice system program as a treatment provider, and educate State agencies as well as treatment providers about the special needs of offenders.

Another valuable contribution the State AOD agency can make is linking the correctional program to licensed treatment delivery. Depending on the setting and type of program, the criminal justice agency's best approach may be to contract with established providers. State AOD agencies can guide criminal justice professionals in selecting the best match between the justice system and a treatment provider optimally suited to providing services to the offender population.

## CSAT's Two-Phased Technical Assistance Program

Since 1991, the Center for Substance Abuse Treatment (CSAT) has advised State AOD agencies to consider offenders' needs when developing statewide plans and strategies for improving treatment. CSAT has been engaged in a major initiative intended to improve linkages at the State level between the substance abuse treatment system and the criminal justice system. CSAT's technical assistance project involves two phases of work with the State AOD agencies that have elected to participate in this effort. This two-phase process helps key decisionmakers in the States begin to see where their agencies and jurisdictions fit into the big picture.

In the first phase, CSAT provides a systemic assessment and organizational analysis of the State's AOD and justice agencies, looking across traditional agency boundaries and examining the overriding roles, decision points, and service responses affecting the AOD-involved offender. The assessment determines where linkages are already in place and where the State might benefit from technical assistance.

After the review process, a developmental action plan for technical assistance is presented to the State AOD director. The plan's recommendations reflect the priorities of the State director, build upon existing State initiatives, and identify leverage points in the systems where technical assistance can have maximum impact. In the second phase, technical assistance is delivered. This TA is sometimes launched by a criminal justice roundtable at which key AOD and justice decisionmakers meet and discuss goals and plans for best using the technical assistance.

## Overcoming Barriers

Open collaboration between the two systems is the approach that best serves offenders and meets the goals of AOD treatment programs. However, some barriers must be overcome before this collaboration can occur.

For example, although some community AOD programs treat nonincarcerated offenders, others may be reluctant to do so. Frequently, this barrier to open collaboration becomes apparent immediately, and sometimes it is difficult to overcome. Another barrier can result from fundamental differences between the two systems. AOD treatment providers are accustomed to working with clients who enter treatment voluntarily, often as self-referrals. Justice "clients" are not voluntary, although their level of cooperation in treatment may be high. Treatment programs may have waiting lists with no pressure to increase their capacity, while system overcrowding may make it impossible for the justice agency to control its population, despite what is known about best criminal justice practices. These basic differences can lead to considerable confusion when both systems negotiate agreements or service contracts.

## Fragmentation of Services Within the AOD Treatment System

Given the fact that the AOD treatment system is still evolving, it is not surprising to find a wide array of services to meet clients' needs. No single approach to treatment works for all persons, and the complexity of the field has arisen largely in response to that truth. Effective AOD treatment is provided by individuals from a wide variety of disciplines, with diverse backgrounds and approaches, with an array of treatment strategies and modalities, and in a variety of settings. Although treatment providers all share the same goal, conflicts sometimes arise when certain groups of providers feel that the efficacy of their approach is not recognized or might be replaced by other approaches and providers. In addition, philosophical differences sometimes divide providers who focus solely on treatment of alcohol abuse and alcoholism from those who focus on drug addiction and use of illicit drugs.

CSAT has been enlarged to a two-phase initiative to improve linkages at the State level between the substance abuse treatment system and the criminal justice system. The first phase determines where linkages are already in place and where the State might benefit from technical assistance. The second phase is the delivery of technical assistance, sometimes launched by a roundtable at which key AOD and justice decisionmakers meet and discuss goals and plans.

Although conflicts have arisen, the AOD treatment field as a whole has grown more sophisticated. Treatment providers from all disciplines increasingly recognize that addiction is a biopsychosocial condition. Given the holistic nature of the disorder, no single group can address the biological, psychological, and social aspects of addiction. The field has made room for all.

The importance of addressing client needs in areas traditionally outside the realm of AOD abuse counseling is being acknowledged. Attempting to meet all of these needs can be a significant undertaking and can lead to a perception that treatment services are fragmented among a number of diverse groups with needs that go far beyond traditional counseling and support. For example, many persons who use injection drugs and share needles acquire human immunodeficiency virus (HIV) and other diseases. To obtain Federal funds, programs must fulfill requirements for providing services to injection drug users, which can further fragment the system by dividing the population to be served. In addition, providing childcare is an important factor in ensuring that some women engage successfully in treatment. Treatment programs that choose to fund childcare sometimes must divert funds from money that would have been used for direct treatment services.

However, some forms of fragmentation are lessening. In many States, the long-standing competition is ending between treatment services for those addicted to alcohol and for those addicted to illicit drugs. An increasing number of States are using terms such as chemical dependency, substance abuse, and alcohol and other drug abuse to describe combined approaches. Most of the philosophical reasons for the distinction between alcohol abuse and illicit drug use are inappropriate, but some practical and clinical factors remain.

While fragmentation has resulted from multiple changes in the AOD system, the same forces have forged flexibility and creative problem solving. Working in a rapidly changing environment takes its toll, but the treatment field on the whole is responsive to new approaches that can lead to high-quality care. As healthcare costs increase, the AOD treatment field is being recognized as a system that can effectively prevent and treat healthcare problems.

### Variations Among States

Understanding the AOD treatment field and its rapid growth and development in the last decade helps explain the wide array of organizational models seen in different States. Many States have umbrella social service organizations that include the AOD treatment system. Sometimes the umbrella organization is the social service, health, or mental health agency. In this model, health, mental health services, and AOD treatment services are in the same organizational branch, but never merged. Some States have created cabinet-level departments or commissions for AOD services.

While fragmentation has resulted from multiple changes in the AOD system, the same forces have forged flexibility and creative problem solving. Working in a rapidly changing environment takes its toll, but the treatment field on the whole is responsive to new approaches that can lead to high-quality care. As healthcare costs increase, the AOD treatment field is being recognized as a system that can effectively prevent and treat healthcare problems.

When criminal justice professionals approach AOD systems, it is advisable to inquire about the stated mission and goals of the larger agency and the working relationship between AOD services and other social and health services. This information may help provide an understanding of AOD treatment, because only a few States deliver AOD treatment services directly. In fact, most contract with certified private treatment providers or county governments.

The necessary involvement of the single State AOD agencies in treatment is generally helpful, but their involvement can also create problems by adding a layer of politics and bureaucracy to the delivery of treatment. For example, some State agencies operate their own AOD treatment programs and may want the criminal justice system to make referrals directly to them, not to community providers.

In many States, county systems play key roles in local needs assessments for prevention and treatment services. These county systems also disburse funds to service providers. Often, county-level working relationships between courts and the AOD system are more collaborative than those at the State level and can be enhanced. County government, unlike State government, often benefits from a sense of community. Cross-system efforts usually are easier and more "natural" with neighbors than they would be in the climate of strained relationships that can exist between State agencies. However, relationships on the local level can be badly strained by a history of not communicating or not working together.

Policy issues can divide AOD professional associations and, in some States, pit the associations against the State or county governments responsible for funding AOD programs. It is recommended that justice professionals ask the State AOD agency about the existence and activities of professional associations and be as inclusive as possible in initial forays with AOD providers.

Some States have a governor-level commissioner or "drug czar," usually with a discrete cabinet-level agency. The commissioner can be a high-level policy coordinator, with responsibility for bridging law enforcement, education, prevention, and treatment activities. Contacting the commissioner can be an effective starting point for justice professionals interested in linkages with treatment resources.

## Federal Block Grants and Other Funding Sources

Understanding State and Federal funding streams for AOD services is important. Each year, approximately $1.2 billion is appropriated by Congress for use by the Department of Health and Human Services (DHHS), Substance Abuse and Mental Health Services Administration (SAMHSA), CSAT. CSAT provides block grant funds, with categorical requirements for expenditures, to each State. States may use no more than 5 percent of these funds for administration and must target 20 percent for primary prevention. The balance is distributed for treatment services with some additional requirements. The regulations put a cap on the amount of block grant funds that can be expended for AOD treatment in correctional institutions; for example, a State could not spend more than the amount of block grant funds expended for this purpose in 1991.

Although the regulations do not require States to serve offender populations, funds are used to provide treatment to individuals with current or past criminal justice status. As described earlier in this chapter, CSAT encourages this use of funds.

In addition to providing block grant funds, CSAT finances demonstration programs in a variety of areas, including service demonstrations for incarcerated and nonincarcerated offenders. Demonstration grants often are awarded through the State AOD agency.

Nevertheless, Federal funding accounts for only a portion of AOD spending. In 1991, for example, $3.2 billion was invested in AOD treatment and prevention services. States provided nearly 40 percent of all funds, and 38 percent were Federal funds. The balance was a mix of county or local government funding, insurance, and client fees. Seventy-five percent of these funds were expended for treatment, 16 percent for prevention, and the balance (less than 9 percent) for capital construction, training, research, and administration to serve over 2 million treatment clients.

## Treatment System Goals

Traditionally, the AOD treatment system has established strong, client-centered goals of recovery and service support. As the complexity of the population and demand for services increased and national as well as local funding requirements emerged, some controversy has arisen about the goals of the AOD treatment system. Some in the field continue to see the trend toward providing a wide range of services for a variety of clients as a threat; provision of these services often requires them to gain additional knowledge and skills outside their area of expertise. Others in the field welcome the changes as responsive to the growing complexity of client populations and their problems, helping ensure better treatment outcomes.

Prevention and a more holistic view of public health are having an impact on the goals of treatment. Increasingly, treatment for AOD abuse is being viewed as allied with public health efforts, particularly at a time when other major public health problems -- HIV, AIDS, and other sexually transmitted diseases, and hepatitis and tuberculosis -- are associated with AOD abuse.

States are increasingly emphasizing prevention, which should be understood in the context of the field's development. Central to the historical goals of AOD treatment was the concept of rehabilitation. Attention was directed primarily toward the client's AOD disorder. Other concerns have evolved within the field, namely, health promotion and prevention of AOD abuse. Prevention initially incorporated information and education strategies. Prevention and a more holistic view of public health are having an impact on the goals of treatment. Increasingly, treatment for AOD abuse is being viewed as allied with public health efforts, particularly at a time when other major public health problems -- HIV, acquired immunodeficiency syndrome (AIDS), and other sexually transmitted diseases (STDs), and hepatitis and tuberculosis (TB) -- are associated with AOD abuse.

Support services, ranging from primary healthcare referral to childcare and employment services, have become important components in the treatment continuum. Emerging AOD treatment programs include these services as part of the continuum of care for persons in AOD treatment.

Few goal statements of treatment providers in recent years have omitted the words "outcome, research, and evaluation." Because of the Nation's growing concern about healthcare spending, programs are increasingly expected to be accountable for the funds they use by demonstrating the effectiveness of the services they provide. Perhaps this emphasis on outcomes evaluation has been the most difficult for providers to accept. Indeed, a major debate continues about measures and which outcomes should be used for accountability. In particular, many people outside the AOD treatment field do not understand the chronic, relapsing nature of addiction. Although many who enter treatment for the first time are able to stop using alcohol and other drugs and remain abstinent, many others require several treatment episodes to achieve long-term abstinence. Policymakers and funders evaluating outcomes data may look only for those data that demonstrate uninterrupted abstinence and overlook other important outcomes, such as significant improvements in a person's ability to function as a parent, worker, or community member, even if that person requires further episodes of treatment.

Many people outside the AOD treatment field do not understand the chronic, relapsing nature of addiction. Although many who enter treatment for the first time are able to stop using alcohol and other drugs and remain abstinent, many others require several treatment episodes to achieve long-term abstinence.

Addressing the many issues surrounding outcomes evaluation is beyond the scope of this TIP. However, readers are referred to another TIP in this series, TIP 14: Developing State Outcomes Monitoring Systems for Alcohol and Other Drug Abuse Treatment, for a full discussion of these issues and how the treatment field has been effected by the growing emphasis on accountability. Another TIP Matching Treatment to Patient Needs in Opioid Substitution Therapy (in development) includes a useful chapter on designing outcomes studies that yield data for improving services and demonstrating accountability.

## Prevention of AOD Abuse

### Prevention Policy

Prevention of AOD abuse should be a central priority at every level -- Federal, State, and local. Communities should systematically examine problems and risk factors related to AOD abuse at the local level to give policymakers and legislators the data they need to create effective laws and policies. For example, legislatures can ensure that money is spent jointly by the criminal justice and AOD treatment systems and that a certain percentage of criminal justice agencies' budgets is set aside for treatment. Legislative action can also change policy on forfeiture of illegally gained proceeds to direct some of these funds into prevention efforts.

One of the most effective ways to implement prevention efforts is to establish community-based multidisciplinary teams. These teams should include representatives of law enforcement, mental health, AOD treatment, public health, social service, and criminal justice agencies. These teams can function as strong mechanisms for gaining community support and involvement.

A model for such action at the community level is the Center for Substance Abuse Prevention (CSAP) Community Partnership program. The program makes grants to communities to develop coalitions of public agencies and private organizations. The aim is to develop comprehensive, self-sustaining, and replicable systems within a community, involving organizations and agencies in the areas of health, education, law enforcement, and social services; grassroots community organizations and religious groups are also involved. The emphasis is on preventing abuse of all drugs, including alcohol and nicotine. The importance of tailoring prevention models to specific cultures is also stressed. More than 250 Community Partnership Grants have been awarded in the past 3 years.

### The Role of the Police in Prevention

The primary responsibility of police is law enforcement and public safety, not social services. However, because police officers work at the community level, they are in a remarkable position to identify and respond to problems, locate resources and alert people about them, make recommendations and facilitate obtaining resources, and provide informal followup. Thus, local police have a critical role to perform in AOD prevention efforts. Police also are recipients of a wealth of information that includes early warning signs and symptoms of impending AOD problems; these signs can be crucial in prevention efforts. Because the use of alcohol and other drugs is so closely linked with criminal activity, especially violent crime, AOD prevention in the community also serves justice system goals of reducing crime and violence and controlling the number of individuals who are incarcerated.

One of the most effective ways to implement prevention efforts is to establish community-based multidisciplinary teams. These teams should include representatives of law enforcement, mental health, AOD treatment, public health, social service, and criminal justice agencies. These teams can function as strong mechanisms for gaining community support and involvement in the prevention of AOD abuse.

However, the principal police intervention is arrest, and police are trained to look primarily for probable cause that can lead to arrest. In many cases, early warning signs and symptoms of AOD abuse precede probable cause for arrest, but police officers may be precluded from engaging in prevention efforts because of their orientation, time constraints, and lack of familiarity with AOD prevention techniques.

- Be cooperative
- Be collaborative
- Be sustained
- Be integrated
- Involve multiple strategies.

Police often meet their primary obligations by identifying current and potential problems, mediating disputes, deescalating crises, and recommending solutions. Many of these activities are remarkably similar to those used by social service providers. When the police are further informed about such topics as addiction, treatment, recovery, codependency, and dysfunctional families and become knowledgeable about local resources, their ability to provide prevention services is greatly enhanced.

In the early 1980s, a new direction in law enforcement began to emerge that has since become known as community policing. The community policing philosophy reaffirms that proactive crime prevention, not merely responding to calls for service, is the basic mission of the police. Community policing takes different forms, depending on the needs of the community in which it is applied. In general, police maintain a visible presence in neighborhoods; officers move from positions of anonymity in patrol cars to direct engagement with the community, giving police more immediate information about problems unique to the neighborhood and insight into their solutions. Police undertake activities to solve crime-producing problems, arrest law violators, maintain law and order, and resolve disputes. At the same time, community policing is anchored in the concept of shared responsibility for community safety and security. In community policing, the police and citizens are partners in establishing and maintaining safe and peaceful neighborhoods; this partnership approach improves relations between police and the public.

In some jurisdictions, community policing includes specific activities to prevent drug abuse and refer people to treatment. For example, in Portland, Oregon, the program features a landlord-training component aimed at reducing drug activity on rental property.

## Criminal Justice System Treatment

As discussed in the previous chapter, the goals of the AOD treatment and criminal justice systems might at first appear to be dissimilar or even antagonistic; however, a more thorough examination reveals shared goals, with a potential for the two systems to complement each other and enhance overall effectiveness.

The benefits derived from such cooperation can flow both ways. AOD treatment for offenders helps the criminal justice system reduce recidivism and gives alternatives to incarceration, when appropriate. Treatment within prisons and jails may ameliorate inmate behavior problems. Policymakers and others are beginning to understand that neither AOD treatment nor criminal justice efforts alone are sufficient to deal effectively with AOD-involved offenders(TIE Communique, 1993).

As discussed in Chapter 1, extensive cooperative efforts have already been undertaken in the form of drug courts and other efforts to divert some substance-abusing offenders into treatment rather than into extensive, costly, and often repeated involvement with the justice system. The national crime bill passed in late 1994 allocated $1.8 billion to drug courts. Drug courts are special courtrooms that integrate substance abuse treatment and justice system case processing under close supervision of a judge. All of these programs involve a conception of the role of the court (and of judges and lawyers) that goes well beyond the traditional narrow view of the court as simply an adjudicative institution and places at least as much emphasis on effective treatment of individuals with substance abuse problems as on the adjudication of cases. All of the programs involve the close collaboration of courts with the treatment community and with other societal institutions in the design and ongoing operation of a program.

It is beyond the scope of this TIP to describe in detail the concepts and operations of drug courts and other forms of alternative case processing. However, other TIPs in this series, TIP 23: Integrating Alcohol and Other Drug Abuse Treatment With Pretrial Processing of Criminal Cases and Combining Alcohol (http://text.nlm.nih.gov/ftrs/dbaccess/tip23) and TIP 21: Combining Alcohol and Other Drug Abuse Treatment with Diversion for Juveniles in the Justice System (http://text.nlm.nih.gov/ftrs/dbaccess/tip21) examine the cooperation of the two systems in these areas.

As reflected in the CSAT Criminal Justice Treatment Planning Chart (see Appendix B), AOD interventions, including screening and assessment, education and prevention, and treatment, are appropriate at every stage of the justice system continuum, from arrest through parole and mandatory release. Linkages at every level will further ensure that treatment follows the offender through the justice system.

### Approaching the AOD System

A careful analysis of the AOD system is needed to prepare for joint program strategies. Those with experience in the treatment-justice linkage are aware of problematic issues. Fortunately, a variety of mutually beneficial public policy agendas exist that can be used to facilitate collaboration between justice and treatment. The effort to control AOD abuse can bring the justice and AOD systems in closer proximity to each other. While many view the end of one system's responsibility as the beginning of the other's, professionals in both systems now have a better understanding of the repetitive, circular nature of the interactions among the justice system, the AOD treatment system, and the community.

### Incarcerated AOD-Involved Offenders

AOD education and treatment differ depending on whether the targeted population is confined to a jail or a prison. While prison terms are generally measured in years, jail sentences are generally measured in days and months. Short stays, varying lengths of stay, and frequent disruptions such as court appearances, combined with overcrowding and understaffing, can make some jails less than ideal settings for effective AOD treatment. However, as discussed above, with adequate resources and careful linkage planning, effective treatment can be provided, or at least begun, in jails. In particular, given the characteristics of jails, flexible programming from community providers is critical. Some of the most innovative and creative AOD treatment approaches are taking place in jails. These range from educational and outpatient treatment services to entire jail facilities committed to treatment.

Regional collaborations among some jail jurisdictions have led to coordinated programming, including work-release programs, interventions related to driving while intoxicated (DWI), drug abuse education, and special treatment services. Jails also provide opportunities to identify lower risk populations that can be treated in separate, lower security facilities.

AOD treatment providers assisting incarcerated populations often must work in difficult situations with constraints on space, resources, and offender movement. If possible, inmates receiving AOD treatment should be segregated from the rest of the jail or prison population, although the lack of resources makes this arrangement impractical in many institutions. Segregation of inmates receiving treatment would permit the establishment of a supportive social milieu within the institution. The social milieu, in which individuals in treatment participate in a structured program and form supportive bonds with others in treatment and with treatment staff, has long been a critical aspect of recovery from AOD abuse and dependence.

The benefits derived from cooperation between the criminal justice system and AOD treatment system can flow both ways. AOD treatment for offenders helps the criminal justice system reduce recidivism and gives alternatives to incarceration, when appropriate. Treatment within prisons and jails may ameliorate inmate behavior problems. Neither AOD treatment nor criminal justice efforts alone are sufficient to deal effectively with AOD-involved offenders.

### Referrals

Referral to appropriate AOD treatment, whether it is in the community or in a correctional facility, is a critical element of cohesive and continuing service for the AOD-involved offender. To make an effective referral, criminal justice and AOD treatment personnel must know what resources are available to address not only the offender's AOD treatment needs, but also needs in the areas of mental health, medical care, and vocational and social services. In addition to knowing available resources, staff also should have a general understanding of how different programs operate and how staff can access services. For example, staff should know specifically which types of programs will accept referrals and their hours of operation, costs, rules, and expectations. Staff also should be able to explain how a program works and what an offender can expect from it. Similarly, staff should be able to assess a program's ability to meet the offender's treatment needs and whether the offender can benefit appropriately from each treatment approach. The most effective referral procedures are developed when personal contact and relationships are involved. For this reason, criminal justice and AOD treatment staff should make active attempts to establish personal relationships and linkages.

- Knowing how the resources operate
- Understanding their rules, hours, costs, and expectations
- Knowing that each referral made is a good match
- Developing personal relationships with resource providers.

### Referral Feedback

Rapid and open feedback helps make the AOD treatment and criminal justice systems function more effectively. Clear procedures are a foundation for timely feedback and rapid action and for establishing ongoing trust in the partnership of the systems.

As described in more detail in Chapter 8, Federal and State regulations protect the confidentiality of individuals who are receiving AOD assessment, referral, or treatment services. Special procedures must be established for sharing information about offenders in treatment. Some criminal justice personnel believe that confidentiality requirements impede feedback. However, routine use of consent forms can help overcome the perception of confidentiality as an obstacle. Unfortunately, feedback between the systems about referrals can be disjointed or nonexistent. Thus, in many jurisdictions, formal arrangements and coordination are necessary to channel appropriate information to relevant staff.

### Pretreatment for Incarcerated Offenders

Pretreatment is the process of educating, preparing, and motivating individuals for treatment when appropriate programs are not immediately available. The pretreatment process is intended to prepare offenders for treatment by

- Providing education about recovery
- Increasing self-awareness regarding abuse and addiction and their effects on individuals and their families
- Providing understanding of the need for treatment
- Increasing awareness about solutions and resources
- Generating treatment motivation.

Although pretreatment is appropriate at every stage of the justice system for both nonincarcerated and incarcerated individuals, it is particularly useful in correctional facilities when there is a waiting list for community-based programs or limited capacity for institutional treatment. In institutions where no treatment is available, pretreatment helps individuals make the transition from being inmates to being participants in AOD treatment programs when they become available, and it helps to demystify the treatment and recovery process.

Pretreatment efforts can include education about the drugs of abuse and their effects, the effectiveness of treatment, and the benefits of living a drug- and alcohol-free life. In jails, where some offenders have very short stays, flexibility of pretreatment programming is essential. Based on needs assessment of their jail populations, personnel can decide which pretreatment components are critical to engaging individuals in treatment and divide pretreatment curricula into flexible units.

A treatment plan developed at this stage can address vocational, familial, and social issues that will help support treatment goals, minimize the risk of relapse, and decrease the risk of criminal behavior.

### Transition From Institution to Community

It is important to recognize the need for offenders to make a smooth transition into the community, a process that involves identifying and addressing special needs before the offender's release from the institution. For those who have served a full term and for whom there are no conditions of release, incentives should be given to participate in treatment after incarceration. For example, increased contacts with and support from AOD counselors in the weeks prior to release may provide some offenders with the necessary incentive. Separate support groups for offenders who have received treatment while incarcerated and who are anticipating release can provide valuable peer support for remaining AOD free. These groups can invite treatment "alumni" who have successfully made the transition to the community. Meetings with offenders' families when appropriate prior to release can also enlist additional support. Such efforts can be effective for all offenders anticipating release, including those who will be paroled and for whom continuing treatment will be a condition of release.

- Biopsychosocial in nature
- Multidisciplinary in delivery
- Comprehensive in scope
- Driven by ongoing assessments
- Closely monitored.

At the end of the period of incarceration, recommendations about community-based treatment programs should be incorporated into parole plans. The case manager or AOD treatment coordinator should be involved in establishing the conditions of parole when appropriate. Sanctions regarding the offender's performance while in treatment also should be discussed in detail with the offender, appropriate community treatment program staff, and the parole officer.

The initial hours and days following an offender's release are critical with respect to relapse prevention and recidivism. There is a high rate of relapse shortly after release. Careful monitoring, especially over the first few days, is imperative. The first 24 hours after release can be especially critical, and there must be a system in place to ensure that an individual released from incarceration gets into treatment or a support group quickly. In many systems, 72 hours can elapse between the time offenders are released and the time they are required to see their parole officers. This time period should be shorter for those who have received AOD treatment services within the correctional system so that treatment goals are reinforced on a continued basis.

It is often preferable for the parole officer to accompany the offender to the treatment program after release. Because accompanying the offender raises issues of confidentiality, an effective parole officer will obtain a signed consent form from the offender before release, ensuring that he or she can provide this support in the initial period after release.

Ideally, a treatment slot should be identified and selected for use when an offender returns to the community. If a treatment slot is unavailable, temporary drug-free housing should be provided. Although self-help groups such as Alcoholics Anonymous (AA), Narcotics Anonymous (NA), and Rational Recovery are not treatment, when a treatment slot is not available, these programs can often provide the structure to support the offender in the community until a slot becomes available. Representatives of local treatment programs, as well as self-help representatives, can be invited to the institution so that offenders have some contact and familiarity with these programs prior to release.

In their role of protection of the community, parole officers often devote much of their attention to offenders with the lowest prospects of success. They should not overlook offenders who have made progress in treatment and who have high potential for success if the transition to the community has been carefully planned and implemented and if ongoing supervision and support are provided. For all parolees, no matter how responsive they have been to treatment, control and treatment effectiveness go hand in hand.

Offenders with previous AOD abuse histories should be closely monitored on a daily basis for the first 30 days after release. Monitoring should include random urine testing and breath analysis. During the parole period, monitoring should be intensive. As treatment progress is made, monitoring can be tapered. Electronic monitoring can be arranged for special groups of offenders so their activities are known to corrections officials. This strategy responds to the security concerns of the criminal justice system while allowing offenders to participate in treatment programs.

It is important that treatment programs provide the criminal justice system and the offender with specific plans that describe the frequency and duration of treatment contacts and the consequences of noncompliance. Immediate and decisive action should be taken when offenders fail to show up for treatment or follow their treatment plan. The treatment program should provide feedback to the correctional system in such cases, and appropriate sanctions should be applied.

The first 24 hours after release can be especially critical, and there must be a system in place to ensure that an individual released from incarceration gets into a treatment program.

Treatment agencies must be able to demonstrate that they are providing an appropriate level and intensity of treatment for each person they serve. The criteria used to determine placement, placement changes, and discharge, should be used system wide and should be based on the severity of AOD problems, not the offense. These criteria should be acceptable to criminal justice administrators.

## Treatment Components

AOD addiction is a chronic relapsing disorder that is influenced by numerous interacting biological, psychological, and social factors. To provide AOD treatment that addresses these biopsychosocial aspects of addiction, a full range of services should be available to the offender. These can include

- Evaluation and assessments -- medical, psychiatric, and addiction
- Detoxification
- Medical assessment, pregnancy tests, and treatment for HIV disease and AIDS, other sexually transmitted diseases, and TB
- Hospitalization
- Treatment planning -- medical, psychiatric, and addiction
- Counseling -- group, individual, and/or family
- Residential treatment
- AOD treatment education: didactic lectures, interactive groups, videos, reading assignments, and journal-writing assignments
- Relapse prevention services
- Crisis intervention
- Drug testing and monitoring
- Self-help education and support
- HIV disease and AIDS education, testing, and counseling
- Comprehensive pregnancy management: prenatal care, parenting classes, and/or childbirth classes
- Mental health services -- medications when indicated
- Social and other support services for the offender and family members
- Vocational and educational training
- AOD treatment services for family members and significant others
- Family services not related to AOD treatment
- Acupuncture for short-term control of AOD craving and other nontraditional adjuncts
- Services for special populations: people who are violent offenders, incest survivors and incest perpetrators, survivors of physical and sexual abuse, and individuals with coexisting AOD and psychiatric disorders.

In addition, a variety of adjunct services may be needed to address sexual abuse, child abuse, domestic violence, victimization, guilt and remorse, and family issues. These issues can be addressed on an individualized basis with case management and coordination.

CSAT has developed a Model for Comprehensive Alcohol and Other Drug Abuse Treatment (Exhibit 5-1). Although it is not designed specifically for offender populations, it is included here to provide readers with an overview of the multiple services that have been shown to improve the effectiveness of AOD treatment.

Exhibit 5-1 Center for Substance Abuse Treatment Model for Comprehensive Alcohol and Other Drug (AOD) Abuse Treatment

A model treatment program includes

- Assessment, including a medical examination, drug use history, psychosocial evaluation, and where warranted a psychiatric evaluation, as well as a review of socioeconomic factors and eligibility for public health, welfare, employment, and educational assistance programs.
- Same-day intake to retain the patient's involvement and interest in treatment.
- Documentation of findings and treatment to enhance clinical case supervision.
- Preventive and primary medical care provided onsite.
- Testing for infectious diseases at intake and at intervals throughout treatment, for infectious diseases such as hepatitis, retrovirus, tuberculosis, HIV/AIDS, syphilis, gonorrhea, and other sexually transmitted diseases.
- Weekly random drug testing to ensure abstinence and compliance with treatment.
- Pharmacotherapeutic interventions by qualified medical practitioners, as appropriate for those patients having mental health disorders, those addicted to opiates, and HIV-seropositive individuals.
- Group counseling interventions to address the unique emotional, physical, and social problems of HIV/AIDS patients.
- Basic substance abuse counseling, including psychological counseling, psychiatric counseling, and family or collateral counseling provided by persons certified by State authorities to provide such services. Staff training and education are integral to a successful treatment program.
- Practical life skills counseling, including vocational and educational counseling and training, frequently available through linkages with specialized programs.
- General health education, including nutrition, sex and family planning, and HIV/AIDS counseling, with an emphasis on contraception counseling for adolescents and women.
- Peer/support groups, particularly for those who are HIV-positive or who have been victims of rape or sexual abuse.
- Liaison services with immigration, legal aid, and criminal justice system authorities.
- Social and athletic activities to retrain patients' perceptions of social interaction.
- Alternative housing for homeless patients or for those whose living situations are conducive to maintaining the addicted life-style.
- Relapse prevention, which combines aftercare and support programs such as the self-help groups Alcoholics Anonymous and Narcotics Anonymous, within an individualized plan to identify, stabilize, and control the stressors that trigger and promote relapse to substance abuse.
- Outcome evaluation to enable refinement and improvement of service delivery.

### Screening and Assessment

A detailed discussion of AOD screening and assessment, which are fundamental first steps in identifying persons with AOD problems, is beyond the scope of this TIP. A companion TIP in this series, TIP 7: Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System, specifically addresses these processes. It describes a variety of screening tools and assessment instruments commonly in use, specifically for offender populations. Many of these are reprinted in full in Appendix C of that TIP. Particularly useful assessment instruments that are included are the Offender Profile Index, which is used to determine the appropriate type of AOD abuse treatment for the offender (for example, long-term residential, intensive outpatient, or regular outpatient); the Addiction Severity Index (ASI), which is probably the most widely used standardized diagnostic instrument in the field; and the AIDS Initial Assessment Jail Supplement, which gathers information about HIV risk factors. The following discussion summarizes many of the points discussed more fully in that TIP. Screening and assessment are important procedures that are used to identify and describe an individual's AOD abuse problems. However, screening and assessment are distinct and are used differently. Screening is an initial process that identifies individuals who are likely to have AOD problems and indicates which individuals need AOD assessment. Screening generally includes the use of urine toxicology tests, which are laboratory methods of detecting the presence of drugs. Blood tests are often used to determine the level of alcohol and to provide an indicator of intoxication. Because laboratory tests indicate only recent ingestion of a substance, brief screening questionnaires are frequently used to supplement laboratory results. Questions about the amount and frequency of AOD use and patterns of use have been found to be very effective in identifying persons with AOD disorders. Problems related to AOD use, such as decreased ability to function at home or at work, are also indicative of AOD disorders.

An AOD screening should be completed for all offenders entering the criminal justice system. Screening in jails can be conducted during pretrial release interviews. When offenders score positively on an AOD screening, they should receive a biopsychosocial assessment by an addiction professional. The assessment should then be combined with a corrections assessment that addresses other issues such as the offender's security needs and risk to the community. Professionals in both systems should exchange information and assessment results to create a sound basis for case management and to develop a holistic approach to decisionmaking.

An AOD assessment is an interview that helps determine the extent of an individual's problem with alcohol and other drugs and the appropriate level of treatment. For example, the assessment may find that an individual is addicted to cocaine as well as alcohol. The assessment also identifies problems related to AOD abuse in an individual's life. Assessments should be biopsychosocial in nature and should address medical, psychiatric, psychological, emotional, social, familial, nutritional, legal, and vocational areas to determine the levels of treatment intervention and services that will be needed.

While an AOD screening is generally a one-time event, an AOD assessment should be approached as an ongoing process. Assessment is repeated throughout treatment and throughout the offender's involvement in the criminal justice system. Changes in the offender's severity of addiction and in problems related to addiction, as well as new life problems and crises, require modifications in the treatment plan.

### Treatment Planning

Based on the results of the assessment, a treatment plan is developed that describes concrete goals and objectives to help the offender correct problems identified in the assessment. The treatment plan, revised periodically based on continuing assessment, should follow the offender through the criminal justice system for continuity of care and treatment planning.

In making decisions about appropriate treatment, patient-treatment matching is an important concept. In patient-treatment matching, every effort is made at each stage of treatment to identify a specific individual's needs, both for AOD treatment services and other services and to secure the appropriate services to match these needs. This approach has been found to increase retention in treatment and improve treatment outcomes. The evolution of this concept in the AOD treatment field reflects the growing understanding of the diversity of patient populations and needs. It also reflects the pressures on the treatment field, as on all areas of healthcare, to reduce costs by eliminating unnecessary and inappropriate treatment.

Another TIP in this series, TIP 20: Matching Treatment to Patient Needs in Opioid Substitution Therapy, (http://text.nlm.nih.gov/ftrs/dbaccess/tip20) includes discussions of key issues in patient-treatment matching, addressing, in particular, the importance of ongoing assessment.

Even if treatment or services for special needs cannot be provided or is provided only partially, treatment options and resources should be identified and contacted. For this reason, active liaisons with community treatment and social service agencies should be developed. Treatment should take into consideration a broad range of issues, including the crimes for which the offender was sentenced, medical concerns including possible HIV infection, mental health problems, and issues related to assault by other offenders. Staff from both systems can then select from an approved "menu" of various treatment components.

When offenders score positively on an AOD screening, they should receive a biopsychosocial assessment by an addiction professional. The assessment should then be combined with a corrections assessment that addresses other issues such as the offender's security needs and risk to the community. Professionals in both systems should exchange information and assessment results to create a sound basis for case management and to develop a holistic approach to decisionmaking.

The evolution of the concept of patient-treatment matching in the AOD treatment field reflects the growing understanding of the diversity of patient populations and needs. It also reflects the pressures on the treatment field, as on all areas of healthcare, to reduce costs by eliminating unnecessary and inappropriate treatment.

The biopsychosocial multidisciplinary approach proposed here, and described more fully in the TIP Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System, will provide data to make informed decisions in the best interests of the offender and the community. Planning for community reentry should begin when offenders first enter the criminal justice system, and conducting assessments early in the process can facilitate that planning.

### Relapse Prevention

Relapse, or resumption of AOD use, should be understood as a characteristic of addiction that often cannot be avoided. Individuals who become addicted to alcohol and other drugs generally do so in an environment that encourages and supports AOD use. Many use AODs to cope with emotions, moods, and negative or traumatic life events and stressors. Many environmental factors, including persons, places, and times of day, are associated strongly with AOD use. All of these factors can trigger strong desires to resume AOD use.

Relapse prevention is a strategy to train AOD abusers to identify the stressors and triggers in their daily lives that may lead them back to AOD abuse and to train them to cope more effectively to overcome obstacles to recovery. In linkages between the treatment and criminal justice systems, educating court personnel, especially judges and other persons in the justice system about the dynamics of relapse is crucial.

CSAT has developed a Technical Assistance Publication Relapse Prevention and the Substance-Abusing Criminal Offender that provides an overview of the recovery process and describes approaches for preventing relapse, as well as specific relapse prevention programs in various States.

Relapse rates are high in offender populations. Relapse prevention is critical and should be part of each AOD-involved offender's treatment plan. Relapse prevention skills and activities should continue throughout the treatment process and be a particular focus for incarcerated offenders prior to release. Personal relapse plans should be developed for all parolees. The plans should include substantive input from offenders, with the understanding that after release they will be involved in making decisions about their own lives.

When relapse occurs, as it does for many in recovery, response to it is a critical element of treatment. Relapse should not be viewed as failed treatment or evidence of personal failure. Often, if properly handled, relapse can lead to increased motivation for recovery, strengthening an individual's knowledge of his or her limitations, the dangers inherent in stressors and triggers, and the individual's awareness of what he or she might lose by leaving the treatment process.

When an offender at any stage of the justice continuum and at any stage of treatment experiences a relapse, it is crucial to assess its seriousness and determine what interventions are indicated. One positive urine test or one drink after long abstinence should not be viewed as failure. Relapse should be seen as a signal noting the need for increased treatment and closer monitoring. However, because resumption of AOD abuse may lead to resumption of criminal activity, addressing relapse raises special issues. The key to renewed intervention is graduated sanctions, specified in an established treatment plan. It is essential that personnel from each system agree on the range of responses to relapse and the times that certain responses are appropriate. Many integrated systems have developed agreements in which the treatment program responds to issues of treatment noncompliance, such as relapse, and the criminal justice system responds to noncompliance with other conditions of probation or release.

Relapses must have consequences for the individual in the treatment, particularly repeated relapses. Decisions on consequences must be case management decisions based on the danger to the community and treatment progress of the offender. Sanction possibilities for relapse include

- House arrest
- Electronic monitoring
- Day treatment
- Brief jail stays.

When relapse occurs, as it does for many in recovery, response to it is a critical element of treatment. Relapse should not be viewed as failed treatment or evidence of personal failure. Often, if properly handled, relapse can lead to increased motivation for recovery, strengthening an individual's knowledge of his or her limitations, the dangers inherent in stressors and triggers, and the individual's awareness of what he or she might lose by leaving the treatment process.

### Drug Testing and Monitoring

Drug testing generally refers to the testing of bodily fluids to determine if drugs are present. Urine is the most frequently tested bodily fluid, but blood can also be tested. Testing for the presence of alcohol is usually done on breath. In addition to providing information about the presence of illicit drugs and alcohol, testing can also provide information about medications prescribed for AOD abuse, such as disulfiram (Antabuse) for alcohol abuse and naltrexone (Revia) for heroin use (and now approved to treat craving for alcohol (O'Malley et al., 1992; Volpicelli et al., 1992), and medications prescribed for psychiatric problems. In addition to testing urine, breath, blood, and, in some cases, hair can be tested.

Drug testing is a vital part of AOD abuse treatment and provides a tool for determining an individual's progress in treatment and for making decisions about changes in the treatment plan. AOD abuse counselors encourage their clients to view drug testing from this perspective -- not as a punitive measure or as a way to control the individual, but as a tool that allows the counselor and client to better achieve treatment goals. In the criminal justice setting, drug testing is used for monitoring offenders' behaviors and ensuring that they comply with conditions set by the courts. Urine drug testing is an area where the differing goals of the two systems are highlighted.

Drug testing should be both a supervisory device and a therapeutic tool. For some offenders, urine testing is an important way to prove objectively to themselves and others that they are making progress. For others, urine testing can be an external source of motivation that helps them achieve abstinence. Drug testing should start at the beginning of the criminal justice process and continue from pretrial to arraignment and throughout the offender's involvement with the justice system, including parole and probation. It can be used in the context of progressive sanctions. Because drugs are available in jails and prisons, urine drug tests should also be used in those settings. Treatment programs that implement urine drug testing for incarcerated offenders will establish credibility with criminal justice officials. Testing should be done on a frequent and unscheduled basis. High-risk clients with previous recidivism and relapse experiences require strict monitoring programs to ensure treatment compliance. The sanctions that will be used in response to positive drug test results should be clearly specified.

### Self-Help Groups

Self-help groups are frequently a crucial component of recovery for individuals in AOD treatment and can be especially important in providing support to recovering offenders. Self-help groups provide peer support and confrontation, and they serve as therapeutic bridges from incarceration to the community. They also help during crises and with personal growth. The best known self-help groups are AA and NA. However, there are other self-help groups that may be appropriate, depending on the offender's beliefs, needs, and interests. These include Survivors of Incest Anonymous (SIA), Rational Recovery, Secular Organizations for Sobriety (SOS), church groups, and feminist and veteran support groups. However, these groups are not a form of treatment, and attendance at meetings should not be used as a sanction.

- Support for AOD treatment and recovery
- Peer support
- Healthy peer confrontation
- Therapeutic bridges between the criminal justice system and the community
- Crisis prevention and management
- Personal growth.

## Case Management

Case management is the process of linking individuals in the treatment system with needed services in addition to AOD treatment, particularly when services are located at different sites and are provided by a variety of agencies. Supplementary services that can be provided include medical, dental, and mental healthcare; childcare and assistance in maintaining custody; housing; educational and vocational training; legal aid; and assistance in obtaining entitlements such as Medicaid and public assistance. Case management originated in the social work profession and has become standard practice in the social services and mental health fields. It is increasingly used in the AOD abuse treatment system to improve treatment effectiveness by ensuring that clients receive supports and services that enable them to continue in treatment and make the best use of treatment and other services.

In the treatment of offenders, case management creates a bridge between the treatment system and the criminal justice system and provides a way to coordinate a mutually reinforcing relationship. The case management process helps ensure that offenders meet both criminal justice and treatment system requirements by focusing on the treatment plan and the goals agreed upon. Case management creates a network of community and private agencies, criminal justice programs, and treatment programs and supports to fill service gaps. Within the criminal justice system, case management also ensures continuity in the transitions from arrest to pretrial or from incarceration to parole.

The case management function ideally starts at pretrial and continues throughout the treatment process. Policies and operations should be particularly focused on providing coordinated services during transitions between stages of the justice system. Parameters for accountability between the two systems should be clearly defined and should ensure proper and timely reporting to both systems.

Critical case management issues include identifying those who have a specific responsibility for the offender and those who make treatment decisions. Written agreement must be reached about the roles of involved agencies. Cross-training and memorandums of agreement between the AOD treatment program and the criminal justice system should be signed.

Selected case management approaches include

- Case management provided by the justice system. In this model, justice system case managers are assigned caseloads at specific stages of the system, such as probation or parole. An advantage of this model is ownership by the criminal justice system of the case management process. Justice system officials are invested in the process because their own staff are implementing it and reporting back to them. A major disadvantage is that this process can be expensive.
- Case management provided by a treatment agency. One advantage of this model is that the case manager has a thorough understanding of the AOD treatment process. The model is community based. The disadvantages include the expense and the possibilities that the case manager may not be familiar with the criminal justice system or that the AOD treatment agencies may not have the resources for effective case management.
- Case management provided by an agency separate from the treatment and justice systems. To reduce costs, this model could employ a case management coordinator, with or without a caseload, to conduct intake interviews and supervise paraprofessional staff. The disadvantages of this approach include the addition of another agency to the collaboration and the expense.
- Case management provided by a coordinator from the justice system who provides consulting services and technical assistance to support existing criminal justice case management. One advantage of this model is system ownership. A coordinator, with or without a caseload, oversees the work of a paraprofessional staff. The coordinator can move the criminal justice system toward a greater awareness of treatment issues by providing technical assistance that demonstrates service coordination.
- Case management provided by multidisciplinary groups in the criminal justice system for offender management. This type of group may meet regularly and during crises. This model is the most inexpensive. However, it is the most difficult to successfully operate because no one is assigned overall responsibility for the offender.

## Treatment Types and Modalities

### Detoxification

Detoxification is the term used to describe withdrawal from alcohol, illicit drugs, or prescription medications that have been abused or misused. Detoxification, as the word implies, entails a clearing of "toxins" from the body. The most immediate purpose is to safely alleviate the short-term symptoms of withdrawal from chemical dependence, including physical discomfort.

Detoxification may occur in either an inpatient or an outpatient setting. It involves several procedures for therapeutically supervised withdrawal and abstinence over a short term (usually 5 to 7 days but sometimes up to 21 days), often using pharmacologic treatments to reduce patient discomfort and reduce medical complications such as seizures. It is a first step for many patients who will enter treatment, but it is not synonymous with comprehensive, ongoing treatment. The detoxification process entails more than the removal of alcohol and other drugs from the body; it includes a period of psychological readjustment that prepares the individual to enter ongoing treatment.

Detoxification is a first step for many patients who will enter treatment, but it is not synonymous with comprehensive, ongoing treatment. The detoxification process entails more than the removal of alcohol and other drugs from the body; it includes a period of psychological readjustment that prepares the individual to enter ongoing treatment.

Withdrawal from certain drugs such as sedative-hypnotics, alcohol, benzodiazepines, and barbiturates can include life-threatening seizures. Thus, it is recommended that medical detoxification be provided for these classes of drugs. Another TIP in this series, TIP 19: Detoxification From Alcohol and Other Drugs, (http://text.nlm.nih.gov/ftrs/dbaccess/tip19) describes clinical detoxification protocols for a variety of substances.

Within the criminal justice setting, there is a broad range of models, from intensive medical management in an inpatient setting to medication-free detoxification in a community-based outpatient setting. Acupuncture is increasingly used as a medication-free approach to relieving some of the discomfort of withdrawal. While many institutions do not provide pharmacologic assistance, others provide some medical management, such as dispensing medications that minimize some of the acute withdrawal symptoms.

Offenders should be educated about the withdrawal process and the type of detoxification they will receive. During withdrawal, people frequently become worried that the symptoms they are experiencing will last for prolonged periods. When educated about the expected course of their symptoms, offenders can deal more easily with withdrawal. Similarly, when offenders, AOD clinicians, and criminal justice staff all share an understanding of withdrawal, it is less likely that staff will misinterpret related behavior as purely manipulative.

Few jails have formal detoxification programs. When an offender is arrested and booked, he or she is screened for medical or other conditions that may need immediate attention. Intoxicated offenders are often held in medical services units under observation until the AOD effects diminish. If they need further intervention to treat withdrawal symptoms, they are transferred to the jail medical clinic or to a hospital, if necessary.

From an AOD treatment provider perspective, this situation raises several concerns. Many would characterize this as a "drunk tank" approach to detoxification. Jails are not certified to perform detoxification, and corrections personnel are not adequately trained. Further, detoxification is generally regarded as the first step into treatment, and how it is handled has a significant effect on treatment engagement and outcome. A more help-oriented model of detoxification is needed in a jail setting, a model that would pave the way for ongoing treatment while recognizing the importance of detaining violent or otherwise harmful individuals who threaten public safety.

### Inpatient Treatment

The most intense levels of treatment are medically managed and medically monitored intensive inpatient hospitalization. At these levels of care, offenders are hospitalized. They can receive treatment for detoxification, medical problems associated with or unrelated to addiction, and psychiatric disorders, although not all individuals need these services. Participants also engage in psychosocial treatment for addiction that can include education, group therapy, and self-help.

Medically monitored intensive inpatient treatment usually provides 24-hour nursing care under the direction of a physician. In contrast, medically managed intensive inpatient treatment has 24-hour medical care in an acute medical-care setting. This approach is valuable for patients who have severe withdrawal or biomedical, emotional, or behavioral problems that require primary medical treatment.

### Residential Treatment

Residential treatment incorporates several different models, approaches, and philosophies for the treatment of AOD disorders that involve cooperative living for people receiving treatment. Specific residential treatment approaches with various lengths of stay have been designed for offenders. Residential treatment programs vary with regard to intensity of treatment. Some programs provide treatment services 8 or more hours a day, 5 to 7 days a week, with clinical staff available both days and evenings. Other residential programs are recovery homes for employed residents, with evening and weekend AOD treatment and limited onsite staff supervision.

The physical environments of residential treatment programs vary greatly. The environments include hospitals, facilities on hospital grounds, institutional housing, multiroom houses, sections of apartment complexes, and dormitory-like structures. Residential treatment programs also vary in philosophical approach. Some therapeutic communities provide psychological treatment focusing on a global change in lifestyle and rehabilitation. Other residential programs are biopsychosocial but focus more on treatment and less on vocational counseling, work therapy, and social services. Other residential treatment programs have several self-help group meetings throughout the week, while others encourage or require attendance at community group meetings.

Residential treatment programs may be targeted to special populations. They may be designed for adult or younger offenders, males, females, pregnant women, people who are employed or unemployed, or individuals with psychiatric disorders. Most residential treatment models designed for offenders use a group approach to treatment, recovery, and rehabilitation. The purpose of group-centered residential treatment is to create an environment that duplicates certain aspects of a family. For example, residents in many of these programs must cooperate and collaborate on daily projects such as household chores, laundry, and meal preparation. This approach is therapeutic because it prompts problem solving, communication, goal setting, and combined efforts to accomplish single goals.

All residential treatment should be followed by continued care in an outpatient setting. It is important that residential treatment become part of continuing treatment, as outlined in the assessment and treatment plan. The Federal Corrections Institute in Lexington, Kentucky, has established a treatment program, Atwood Hall, that is an example of an intensive AOD residential treatment program. It includes 12 months of more than 10 hours of daily treatment and 6 months of supervised aftercare. In philosophy, it is a self-help-oriented program that uses group therapy, individual counseling, and large groups to deal with issues of denial, recovery, relapse prevention, and cognitive coping skills.

#### Therapeutic Communities

Therapeutic communities (TCs) are residential programs that allow individuals to phase into independent living. Several types of drug-free residential programs have been developed to treat a wide spectrum of AOD abusers. The traditional TC model involves a long stay, usually ranging from 15 to 24 months, although many modified TCs are structured for 6 to 18 months. The TC model focuses on global rehabilitation in which AOD treatment is incorporated.

The TC approach views AOD abuse and other problems as reflections of chronic deficits in social, educational, vocational, familial, economic, and personality development. Thus, the principal aim of the TC is global life-style change, including abstinence from AODs, elimination of antisocial behavior, enhanced education, constructive employment, and development of prosocial attitudes and values.

The TC incorporates comprehensive rehabilitation services in a single setting. Services include vocational counseling; work, group, and individual therapy; recreation; education; and medical, family, legal, and social services. The primary TC "therapist" is the TC community itself, consisting of peers and staff who model successful personal change. Staff members are usually former AOD abusers who were treated in TC programs and who serve as guides in the recovery process.

The foundation of the TC approach includes structure, mutual self-help, work as education and therapy, peers as role models, and staff as rational authorities. The TC structure encourages offenders to arrive as patients and leave as staff. Job functions are hierarchical and based on seniority, individual progress, and productivity. Work serves to teach offenders how to negotiate social and occupational worlds. Peers and staff encourage self-motivation, commitment to work, positive regard for authority, and an optimistic outlook.

Most residential treatment models designed for offenders use a group approach to treatment, recovery, and rehabilitation. The purpose of group-centered residential treatment is to create an environment that duplicates certain aspects of a family. For example, residents in many of these programs must cooperate and collaborate on daily projects such as household chores, laundry, and meal preparation. This approach is therapeutic because it prompts problem solving, communication, goal setting, and combined efforts to accomplish single goals.

The role of discipline and sanctions within TCs can be particularly valuable for offenders. The explicit purpose of discipline and sanctions is to ensure health and safety. Surveillance can be potent in TCs. One of the most comprehensive forms of surveillance is the "house run," which involves staff and senior residents walking through the facility to examine the overall condition. Examining the facility permits early problem detection. It also provides observable, physical indicators of the use of self-management skills as well as indicators of the attitudes, emotional status, and awareness of residents and staff.

### Outpatient Treatment

Like residential treatment programs, outpatient AOD treatment incorporates several approaches, models, settings, and philosophies. The most obvious difference among outpatient treatment programs is level of care. Outpatient treatment ranges from traditional outpatient services to intensive outpatient treatment (IOT) programs. Traditional outpatient treatment is used here to describe treatment provided by clinical addiction professionals in organized clinical settings. This treatment occurs in regularly scheduled sessions, with usually fewer than 9 contact hours per week. Examples include weekly or twice-weekly individual therapy, weekly group therapy, or a combination of the two in association with self-help activities. Because traditional outpatient treatment involves a limited number of sessions per week, it has been described as nonintensive treatment.

In contrast, intensive outpatient treatment consists of regularly scheduled and structured sessions with a minimum of 9 treatment hours per week. Examples or models include day or evening programs in which clients attend a full spectrum of treatment programming while living at home or in a special residence. Another TIP in this series, TIP 8: Intensive Outpatient Treatment for Alcohol and Other Drug Abuse, describes one approach to this level of care.

Variants of traditional outpatient treatment and intensive outpatient treatment can be adapted to meet the needs of incarcerated and nonincarcerated offenders within the justice system. Within the AOD treatment continuum, intensity decreases over time if an individual meets treatment goals. For example, offenders receiving AOD treatment may initially be placed in inpatient settings during withdrawal, followed by intensive outpatient treatment and continuing care. In contrast, outpatient treatment provided in correctional institutions is often less intense than that provided by AOD programs in community settings. Thus, offenders may receive more intense treatment after leaving a correctional setting, even though they continue to receive outpatient treatment.

Outpatient services can incorporate treatment topics and use group processes consistent with those used during an offender's institutional stay. Treatment or education begun within the institution also can provide a springboard for community outpatient care. Outpatient treatment can be provided to many more offenders for the same level of funding as residential treatment. Thus, outpatient treatment is a cost-effective option for some offenders.

### "Boot Camp" Programs

In response to mandatory drug sentencing, there is a trend in many jurisdictions to develop "boot camp" or "shock incarceration" programs, mostly for young drug offenders. There are currently 47 such camps operating in 27 States and two in the Federal Bureau of Prisons. New York has the largest program, accounting for 30 percent of all inmates in boot camps. The approach incorporates a highly regimented, military-style schedule combined with confrontation, discipline, and behavior modification, in the belief that discipline and humiliation will shock young criminals into shape. The New York State Department of Correctional Services has estimated that the roughly 9,000 boot camp graduates to date have saved the State an estimated $305 million in custody and capital costs (Yen, 1994).

However, there is some question as to whether these programs reduce recidivism among young criminals. A recent eight-State study funded by the National Institute of Justice (MacKenzie and Souryal, 1994) concluded that recidivism rates of "shock graduates" are comparable to those of the general prison population. However, in New York the State Division of Parole has found a statistically significant reduction in recidivism within the first 2 years after release from the camps. After 4 years out, however, the recidivism rate of boot camp graduates was almost identical to the rate of regular parolees. The New York study found that high-quality AOD abuse treatment programming played a significant role in the improved recidivism rates in the first 2 years.

### Opioid Substitution Therapy

Methadone and, more recently, LAAM (levo-alpha-acetyl-methadol) are used as opioid substitutes in the treatment of opiate users. These substitutes prevent withdrawal and block the effects of opiates, discouraging continued use of illicit drugs. With methadone, the individual is required to attend the methadone clinic once every day to ingest the methadone dose. LAAM is a longer acting (72 hours) opioid substitute, and clinic attendance is reduced accordingly when it is administered.

Three TIPs in this series, TIP 1: State Methadone Treatment Guidelines, TIP 20: Matching Treatment to Patient Needs in Opioid Substitution Therapy, (http://text.nlm.nih.gov/ftrs/dbaccess/tip20) and TIP 22: LAAM in the Treatment of Opiate Addiction (http://text.nlm.nih.gov/ftrs/dbaccess/tip22), provide detailed descriptions of this treatment modality and related issues. A controversial issue that is raised in most discussions of methadone is the argument by some that methadone treatment "substitutes one drug for another"; many individuals remain on methadone indefinitely. Some people both inside and outside the treatment field believe treatment should result in a drug-free, or abstinent, state. In fact, in some areas, individuals receiving methadone are considered drug users and cannot enter drug-free treatment or support groups.

Most research, including several very large studies, has shown that participation in methadone treatment is associated with a reduction in illicit opioid use, a reduction in criminal activity, increased employment, and improvement in psychological status (California Department of Alcohol and Drug Programs, 1994; Hubbard et al., 1989; Senay, 1989). In addition, those involved in methadone maintenance treatment receive social, vocational, legal, and educational support services. Methadone maintenance also is an important approach used to reduce the incidence of needle sharing, and it helps reduce needle-spread diseases such as hepatitis and HIV. For many people, methadone maintenance is an opportunity to begin psychosocial stabilization and normalization, an introduction to self-help, and a pathway to abstinence and sobriety.

Offenders must be evaluated both medically and psychologically to determine if methadone maintenance is appropriate. These decisions must be individualized and based on medical history, psychological profile, HIV serostatus, and length of incarceration. Since the early 1970s, methadone maintenance has been recommended as a treatment for opiate-dependent pregnant women. For these women, methadone maintenance prevents erratic maternal opioid drug levels and protects the fetus from repeated episodes of withdrawal. Methadone treatment also can reduce the incidence of obstetrical and fetal complications, in utero growth retardation, and neonatal morbidity and mortality. Maternal nutrition usually is improved and exposure to HIV disease through ongoing needle use can be minimized.

## Criminal Justice Sanctions And Treatment Incentives

After a person is involved with the criminal justice and treatment systems, successful treatment outcomes depend in part on the level of collaboration and cooperation between the two systems. One aspect of this collaboration involves sanctions and incentives. The criminal justice system should have a hierarchy of sanctions available to use in conjunction with treatment incentives and rewards to improve AOD treatment outcomes. Decisions regarding the types and structure of sanctions can be developed jointly by the AOD treatment and criminal justice systems. These sanctions should be applied consistently for positive drug tests, no-shows for treatment, prohibited behavior, or broken program rules. Sanctions should be swift and certain and can include increased frequency of urinalysis, short jail stays, and increased reporting to supervising criminal justice system staff. Another TIP in this series, TIP 12: Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System, gives a detailed overview of sanctions and their effective use.

Both systems can benefit from effectively applied sanctions. For treatment providers, sanctions coupled with rewards help reinforce treatment goals. The criminal justice system can benefit because, once sanctions and rewards are brought into treatment plans, control can be extended and clients are managed more easily.

Substantive incentives, such as reduced jail time or less frequent reporting to parole or probation officers, can encourage offenders to participate in treatment. Offenders also may benefit from knowing that there are or can be advantages for making progress in treatment. Incentives can be used to encourage treatment participation at several points in the criminal justice continuum, starting at arrest and pretrial procedures. Offenders should know that if they enter treatment, alternative sentences may be imposed. Other examples of incentives are safe housing units, additional recreation time, positive parole board review, and the return of children to their mothers. Incentives also can be used to the treatment program's advantage.

Most research, including several very large studies, has shown that participation in methadone treatment is associated with a reduction in illicit opioid use, a reduction in criminal activity, increased employment, and improvement in psychological status. In addition, those involved in methadone maintenance treatment receive social, vocational, legal, and educational support services.

## Conclusions: The Importance Of Linkages and Joint Decisionmaking

As emphasized throughout this document, effective linkages and partnerships are necessary to enhance the relationships between treatment and each stage of the criminal justice continuum. As discussed in the previous chapter, such partnerships can take many forms, including committees, programs, policies, resource materials, manuals, and laws. Both systems must recognize the importance of a unified approach to the problems created by AOD abuse and criminal behavior. In addition, they must acknowledge the need for many groups and agencies to become involved in collaborative activities to reduce AOD abuse. As an offender moves through the criminal justice continuum, there are increasing linkage needs, not only between the criminal justice and treatment systems, but also with other community services and programs.

## Endnote