# Chapter 4—The Criminal Justice Continuum

To plan effective strategies for collaboration, alcohol and drug (AOD) abuse treatment system planners, policymakers, and providers must have a detailed understanding of the workings of the criminal justice system. Terms and concepts used in the justice system are often misunderstood by people outside the system. This chapter presents an overview of the criminal justice continuum, suggesting points at which linkages between the two systems can be created and strengthened.

An important supplement to the information in this chapter is the Center for Substance Abuse Treatment (CSAT) Criminal Justice Treatment Planning Chart, which is included in Appendix B of this document. The chart gives a simplified overview of the criminal justice continuum, showing the flow of cases through the system. The chart shows the major decision points in the continuum and where coordinated strategies for substance abuse treatment interventions may be applied. Accompanying the chart is a glossary of common terms and concepts used in both the criminal justice and AOD treatment systems. It is hoped that criminal justice and AOD treatment systems will adapt and use the chart as a planning and coordinating tool to improve AOD abuse treatment services.

## Overview

Although there are Federal, State, and local differences, the criminal justice system can be viewed as a continuum, the stages of which involve personnel from various justice agencies. Throughout the stages of the continuum, efforts are focused on the common goal of protecting public safety. Major areas of criminal justice processing are

- Arrest
- Arraignment
- Plea bargaining (negotiations leading to disposition or trial)
- Diversion programs
- Trial
- Presentencing
- Sentencing
- Probation
- Intermediate sanctions
- Jails and prisons
- Parole or mandatory release.

To provide the most effective services, AOD abuse treatment providers must work within each phase of the criminal justice system. Personnel should focus on system points of contact at every possible juncture. An understanding of the case-flow process at every stage from arrest to release will enhance coordination. Ongoing communication for managing AOD-involved offenders is critical.

### Supporting and Creating Linkages

Two other CSAT Treatment Improvement Protocols (TIPs) in this series describe diversion of certain individuals from the criminal justice system into treatment in the early stages of their involvement with the justice system. TIP 23: Integrating Alcohol and Other Drug Abuse Treatment With Pretrial Processing of Criminal Cases and Combining Alcohol (http://text.nlm.nih.gov/ftrs/dbaccess/tip23) and TIP 21:Combining Alcohol and Other Drug Abuse Treatment With Diversion for Juveniles in the Justice System (http://text.nlm.nih.gov/ftrs/dbaccess/tip21) address the many issues involved with linking the two systems. The former TIP describes the drug courts that have evolved over the years to handle the increase in drug-related arrests. The latter TIP describes a process of diverting juvenile offenders into treatment before they become entrenched in the criminal justice system.

In addition, a third TIP in this series, TIP 12: Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System, provides detailed guidelines for creating linkages between the two systems primarily after adjudication (trial or sentencing).

### Criminal Justice Referrals

Several different categories of criminal justice system personnel can refer an individual into treatment. However, persons in the AOD treatment system should recognize that the source of the referral is important because it determines whether the individual enters treatment voluntarily or is mandated into treatment. Also, different personnel in the justice system have different motives for referring an individual to treatment and thus will refer in different situations. For example, the bail commissioner may only refer individuals who otherwise would fill the jails, regardless of whether they have AOD problems. Judges tend to recommend treatment only if it relates to the current charge and falls within the requirement for the least restrictive environment. A public defender may refer to treatment only if it will help his or her client's case. If the client needs treatment, but the current charge is unrelated to alcohol or other drugs, there may be no referral because sending the client to treatment could negatively affect the case.

In many of these decisions, the system is focused on the present (and possibly the past) of the client and not on the larger issues of what is good for the client and society as a whole. Many who consider the big picture would say that it is better to get the individual into treatment (regardless of the charge) because recovery will not only improve the health of the individual but also result in decreased crime, safer streets, and reduced cost to society.

## Stages in the Justice Continuum: Arrest and Pretrial

Arrest is the taking of a suspect into legal custody by police, probation or parole officers, and other authorized officials. Arrest may be authorized pursuant to a judicial warrant, which is issued when there is probable cause to believe that a crime was committed and that the suspect committed the crime. Arrest without a warrant may be made by a police officer when there is probable cause to believe a felony was committed and the suspect committed it. Arrests for misdemeanor violations generally require a warrant, except when the arresting officer sees the suspect committing the misdemeanor (for example, in some cases of drug possession). Police have some discretion in whether to make arrests, although several jurisdictions have mandated arrest in certain situations, such as domestic violence or drunk driving.

Following arrest, defendants enter the pretrial period. Typically, they appear before a magistrate in court, bond is set, and they are released under their own recognizance or a determination is made to retain them in jail or under supervision in a detention facility until their trial.

Ideally, police officers would use their community contacts to explore AOD treatment services options for AOD-involved individuals who come to their notice but are not arrested. For many individuals, further involvement in the criminal justice system might be prevented if police were empowered and informed about AOD abuse so that they could make referrals, and if the treatment system were willing to work with the referred clients. "Community policing," which is discussed more fully in Chapter 6, is an approach to police involvement in the community that seeks to overcome negative relationships that arise when police officers are perceived as outsiders by community residents.

Being arrested can motivate some AOD abusers to enter treatment. From a treatment perspective, arrest and the related crisis may have a positive outcome. Arrest is a significant event in a person's life because it may make it difficult for him or her to deny AOD abuse problems. It offers the opportunity for the arrestee to voluntarily choose to enter AOD abuse treatment. Thus it is important for connections to be made between the treatment and criminal justice systems at this point. Representatives from both the criminal justice and AOD treatment systems can see arrest as an important place to set up linkages, begin intervention, and find ways of working together. From the perspective of criminal justice personnel, especially judges, an important aspect of these linkages must be the accountability of treatment providers to ensure that public safety is protected.

Arrest can be a significant event in a person's life because it may make it difficult for him or her to deny AOD abuse problems. It offers the opportunity for the arrestee to voluntarily choose to enter AOD abuse treatment. Thus it is important for connections to be made between the treatment and criminal justice systems at the point of arrest.

It must be noted, however, that involvement of AOD abuse treatment providers at the point of arrest may raise constitutional issues. If the arresting officer considers transfer of the individual to AOD treatment rather than to the criminal justice system (which has laws protecting defendants' rights), questions may be raised about due process, civil liberties, and extension of the criminal justice system beyond permissible bounds. After arrest, the defendant is subject to the authority of the criminal justice system. The level of responsibility granted to the treatment program should be defined clearly, understood by both systems, and incorporated into the information flow between systems.

Pretrial information about a defendant can be grouped into the following categories:

- Criminal record
- Prior compliance with supervision
- Pretrial evaluation
- AOD abuse assessment information
- AOD abuse treatment information.

Basic information gathered about the defendant should follow the offender through subsequent stages of the criminal justice system and AOD abuse treatment system. Agencies from both systems should decide what information is necessary and useful, and should develop methods for sharing that information. However, the defendant's civil liberties and rights of confidentiality must be considered whenever information is shared. These legal issues are discussed more fully in Chapter 8.

## Arraignment and Plea Bargaining

Arraignment is a technical term signifying presentation of the charges to the defendant. In many jurisdictions the term arraignmentis reserved in felony cases for the presentation of charges in the superior court. A first appearance is held in the lower court after arrest for bail setting and probable cause review. This hearing is not referred to as an arraignment.

The period of time between arrest and arraignment is a window of opportunity for intervening and articulating the value of AOD treatment. Drug testing, screening, and assessment for AOD abuse and dependence and for infectious diseases, needs assessment in other areas, and various forms of AOD treatment, as well as relapse prevention, are important components of intervention at this time as well as at other points along the continuum. A multidisciplinary approach is recommended, with treatment providers available to work with police and court personnel to guide drug-abusing offenders into treatment.

During the arraignment, charges are brought against the defendant, and the defendant is informed of his or her rights. The defendant then enters a plea in response. Additional personnel, including staff from pretrial service agencies, judges, prosecutors or defense attorneys, court referral officers, and representatives of referral systems, handle this process and become involved as the defendant moves through the arraignment process. Each of these individuals can refer the defendant to AOD treatment services.

With court overcrowding, plea bargaining is used in a large number of cases. In a plea bargain, defendants are allowed to plead guilty to lesser charges than the charges that they would have to face in a trial. Once the guilty plea is entered, it is up to the judge to determine a sentence. Incorporation of substance abuse concerns into the plea bargaining process is a key element in strategies to link the justice and treatment systems. A requirement that the defendant enter treatment can be part of the plea bargain. Many systems are finding that getting defendants into treatment at this point is successful because they are ready for services. However, just as overcrowded court dockets force the hand of criminal justice system officials on certain decisions, overcrowded caseloads can make it impossible for treatment programs to accept new clients.

Incorporation of substance abuse concerns into the plea bargaining process is a key element in strategies to link the criminal justice and AOD treatment systems.

### Presentencing

Presentencing is the period after a guilty plea is entered (in cases that are plea bargained) or after a conviction is handed down (in cases that go to trial).

Prior to sentencing, a presentence investigation is conducted. The investigation is conducted after the plea is entered or after the conviction is handed down. In some plea-bargained cases, a plea may be withdrawn after the presentence investigation is completed and sentencing recommendations are made.

Many jurisdictions have presentence investigation agencies, which specialize in writing the report. Elsewhere, probation officers compile the report. The sentence or penalty handed down by the judge is based on the information that has been compiled in the presentence report. Therefore, with more relevant information available, the judge will be better equipped to make an appropriate sentencing decision.

This is another point where linkages between the two systems are critical. It is suggested that some sort of AOD intake and preliminary assessment be provided at this stage, if one has not yet occurred in the earlier stages.

In many States, there are serious legal constraints on sharing information contained in the presentence investigation. In some States, only the judge can see the report -- not even the defendant can see it. However, the presentence investigation report may contain information highly relevant to developing an AOD treatment plan for the individual. To avoid duplication of efforts in gathering needed information at various stages of the justice-treatment continuum, planners should investigate ways to facilitate information sharing without breaching confidentiality and to ensure that critical information follows the individual through the process.

#### Drug Courts

Cooperative efforts between the two systems have already been undertaken in many jurisdictions in the form of drug courts and other efforts to divert some substance-abusing defendants into treatment rather than into extensive, costly, and often repeated involvement with the justice system. As discussed in Chapter 1, drug courts are special courtrooms that integrate substance abuse treatment and justice system case processing under close supervision of a judge. It is beyond the scope of this TIP to describe in detail the concepts and operations of drug courts and diversion processes. However, other TIPs in this series examine the cooperation of the two systems in these areas.

### Trial

A trial is a court hearing in which a prosecutor presents a case against the defendant to show that he or she is guilty of an accused crime. A judge or jury decides the verdict. If the verdict is "guilty," the sentence or the penalty imposed in the case is determined by the judge, or, as in several States including Texas and Virginia, the jury determines the sentence. In many States, the sentence or penalty is based partially on the information that has been compiled in the presentence investigation report. Increasingly, States are passing laws to ensure that the penalty is based on the offense without regard to information contained in the report.

### Sentencing

Sentencing is the disposition of a case in which penalties are imposed. Once the defendant is adjudicated (either by plea or jury trial), information in the presentencing report will generally be used to assist in sentencing decisions. The goals of sentencing are to reduce community risk and punish the offender fairly. Some States continue to recognize rehabilitation of the offender as a goal. Deterrence of crime by others by creating an example can also be thought of as a goal of sentencing. Although victim restitution is not a goal of sentencing, a judge may be authorized to require it.

Sentences can be fines, probation or incarceration, or a combination of the two. Sentencing can include house arrest, electronic monitoring, and other community sanctions. Sentencing can also be linked with AOD treatment without increasing the length of the sentence. Sentencing may include outpatient treatment, family therapy, medical care, or placement in a halfway house. In many jurisdictions, public and private agencies have created a wide variety of intermediate sanctions programs, which are described below in a separate section.

Some jurisdictions, such as the State of Colorado, have developed and are implementing a standard set of policies and procedures for offender treatment that includes the items the judge needs to consider in making a sentencing decision. Each offender is assessed and receives a validated assessment score that is used in recommending levels and types of treatment. In San Francisco, the probation staff periodically updates the court, both in writing and in person, about various treatment options that are available to the court at the time of sentencing.

In combining treatment with judicial sanctions, judges have to think creatively, look for innovative approaches, and possibly take risks. Some examples of successful approaches include intensive outpatient treatment, day reporting centers, intensive supervision, curfew or house arrest (with or without electronic monitoring), residential treatment and halfway houses, and boot camps. Judges need a policy that can be used as a basis for decisionmaking and that includes a menu of available options. (See the companion TIP Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System for more discussion of these issues.)

### Probation

Probation is a sentence of community-based supervision. Probation includes stipulations and prohibitions on certain activities and often includes fines imposed by the court at the time of sentencing.

Understanding the purpose and functions of probation requires an understanding of probation's place within the criminal justice continuum. Probation provides supervision for offenders while they engage in a community-based process intended to modify or change behavior. The efficacy of probation is measured by a reduction in the offender's criminal activity and by the offender's ability to perform productively in the community after completing probation. Constructive and positive change by the offender is a tangible demonstration that the system is working effectively. Probation's goals have been statutorily defined by both State and Federal legislative bodies. Probation officers are required to prepare written court reports, advise judges on sentencing recommendations, supervise offenders placed on probation by the court, and report to the court about the conduct and actions of offenders who violate probation.

Probation provides supervision for offenders while they engage in a community-based process intended to modify or change behavior. The efficacy of probation is measured by a reduction in the offender's criminal activity and by the offender's ability to perform productively in the community after completing probation.

Over the years, the role of probation has changed substantially. Probation was initially designed to carry out well-tailored community correction programs for nonviolent offenders. The goal was to aid in rehabilitation by providing a wide range of services for offenders who posed no risk to the community. This is no longer the goal. Increasingly, probation is used to supervise the activities of serious offenders whose needs are dramatically different from those of offenders 30 years ago. Today's probation officers can no longer be concerned with rehabilitation alone, but must be prepared to address offender risk management, crime control, correctional treatment, and habilitation. This change does not mean that today's caseloads are more violent. The great majority of offenders -- about nine out of ten -- who receive probation have not committed violent crimes. However, the needs of current offenders are more complex and require a greater array of specialized services, such as those used in supervising AOD-involved individuals.

Despite the growing emphasis on incarceration since 1980, probation is still the dominant sentencing sanction. The Bureau of Justice Statistics (1994) reported that in 1990, the last year for which data are available, the probation population represented more than 2.5 million offenders; this population has been growing at the rate of 13 percent per year. Although probation is the most frequently used sanction and is employed to supervise the most offenders, its effectiveness is often undermined by a lack of several kinds of support. Carrying out the goals of probation is critically compromised in many jurisdictions by a lack of resources, inadequate funding, and significant reductions in personnel.

To be effective, probation must provide a meaningful sentence from among a range of options available to meet the needs of an increasingly diverse population. Probation officers have had to expand their roles as behavioral specialists in order to match the offender with an appropriate program. Increasingly, probation is being viewed as existing in two forms -- traditional probation and intensive probation. At least two levels of probation should be available to the judge, and supervision should be predicated on community safety and offenders' needs.

For probation officers working with AOD abusers, the maximum caseload suggested by the consensus panel that developed this TIP is 35 clients; this also is the caseload limit recommended by the Federal probation system. In many jurisdictions, however, the probation officer's caseload may be four times that number, an unmanageable size in terms of fulfilling recommended goals.

Although the role of the probation officer has changed in recent years, reflecting the diverse needs of offender populations, many aspects of the role remain unchanged. Probation is a legal disposition. Therefore, controlling, monitoring, surveilling, and enforcing the court-ordered conditions of probation should not be subordinated to the task of helping the offender, but should remain primary tasks. However, out of necessity, many have broadened this conception of the probation officer's role to include that of a case manager, with added responsibilities of bridging and linking systems to engage needed supports and advocating for the offender where appropriate. Probation officers have a critical role in linking the AOD and criminal justice systems.

While the probation officer can be viewed correctly as a behavioral specialist, it is important to note that the probation relationship is not a clinical one in the usual sense. First, a relationship between an adult client and therapist is in virtually all cases a voluntary one that the client can terminate at any time. In addition, except in certain well-defined circumstances, such as when a client reports abusing a child, the client-therapist relationship is protected by ethical and legal confidentiality requirements. (Issues surrounding offender's confidentiality rights are discussed in detail in Chapter 8.)

For example, a client who seeks therapy for bipolar disorder might tell a therapist that he wrote bad checks during a manic episode. The therapist might deal with this issue therapeutically, by discussing the client's feelings about the behavior or its consequences, with the aim of helping the client avoid repeating these behaviors in the future. The client's confession of this criminal activity would reflect his understanding of the special nature of the clinical relationship, which would be encouraged by the therapist. However, if an offender told a probation officer that he had written bad checks, he would not have the same expectation. The probation officer must supervise the offender during probation and ensure compliance with court-ordered sanctions, and would have to report the incident.

It can be seen in these examples that the overall goal of helping the offender avoid criminal activity in the future is the same. When that goal is the focus, especially in jurisdictions that have implemented collaboration between the criminal justice system and the AOD abuse treatment system, the roles of personnel in both systems are not as clear-cut as in the example provided. For true collaboration, there must be a blurring of roles, backed up by accountability. These issues are described more fully in subsequent chapters of this TIP.

## Intermediate Sanctions

Sanctions are legally binding orders of the court or paroling authority that deprive or restrict offender liberty or property. An intermediate sanction is any sanction that is more rigorous (unpleasant, intrusive, or controlling) than traditional probation but less restrictive than total incarceration. With the advent of new technologies for supervision of offenders, new methods of intervention and treatment, and an increased understanding of targeting programs to particular populations, agencies have the means to safely manage and treat offenders in the community.

Another TIP in this series, TIP 12: Combining Substance Abuse Treatment With Intermediate Sanctions for Adults in the Criminal Justice System, focuses exclusively on intermediate sanctions. The following discussion summarizes a few of the issues it addresses.

The particular programs or forms of sentencing that comprise a jurisdiction's intermediate sanctioning options can be determined by the policymakers of that jurisdiction, based on its needs and financial situation. Some of the more widely used options are described in Exhibit 4-1. AOD abuse treatment may be combined with any of these sanctions to achieve the goal of more effective sentencing for AOD-involved offenders. It is important to understand, however, that each jurisdiction, whether a State, a county, or a court district, will have developed its own version of these, and that from area to area, programs may share a name and little else. Combining treatment and sanctions requires that all those with a stake in these programs -- criminal justice and treatment systems representatives and community and government representatives -- develop an integrated policy.

For some, these sanctioning options represent the right approach to sentencing. Many policymakers in the criminal justice system want the ability to determine individualized sentencing and to respond appropriately and effectively to the diversity of offenders and offenses presented to them. The interest of others is driven by profound dissatisfaction with the outcomes of most existing sanctions, including prison, jail, and probation, particularly in light of their cost. Dissatisfaction with current sanctions is probably deepest in cases that involve AOD-abusing offenders.

Others, including criminal justice officials and a considerable portion of the public, believe that intermediate sanctions are necessary because there is simply not enough money to build prisons to incarcerate all offenders. The public is beginning to understand that being jailed or imprisoned is not the only possible or appropriate consequence of criminal behavior. The public will accept creative approaches even for serious offenses and accepts the idea of restitution or meaningful community service, combined with AOD treatment, as appropriate for certain criminal actions.

The goal of intermediate sanctions must be more than merely making probation tougher or diverting offenders from prison. Effective intermediate sanctions for AOD abusers must be more than a series of unrelated interventions. They should encompass a continuum of rationally graded sanctions and control options. The concept of graduated sanctions is a primary factor in the effectiveness of intermediate sanctions. Providing graduated sanctions involves increasing or decreasing requirements, levels of supervision, or limits on movement in order to ensure appropriate and consistent response by offenders. Some examples of graduated sanctions include

- Increasing community service hours
- Adding electronic monitoring to home arrest
- Switching from regular to intensive probation
- Tightening curfew hours.

When AOD abuse treatment is combined with intermediate sanctions, examples of graduated sanctions might include

- Requiring participation in a relapse program
- Increasing frequency of urinalysis
- Moving the offender to a more restrictive treatment program, for example, from an outpatient to a residential program.

### Jail

A jail is a facility that holds both pretrial and sentenced offenders in lawful custody while they await trial, serve short-term sentences of up to 1 year, go on work release, or are subject to weekend incarceration. Jails range in size from tiny rural jails with less than a dozen cells to massive urban facilities housing thousands of inmates. In some jurisdictions, large jails operate like prisons.

With a high turnover rate and relatively short terms of incarceration, jails experience a specialized set of problems. Traditionally, jails have afforded few opportunities for any sustained offender involvement in an AOD treatment program, but this situation is beginning to change. In recent years, jails have begun incorporating programming to address AOD interventions. In some large jails with significant numbers of inmates who may remain for extended periods of time, it is necessary to provide programming similar to that provided by prisons, which includes AOD treatment. For short-term pretrial defendants, the goal of jailing is to ensure their presence at trial. However, for sentenced offenders, treatment goals can be similar to those in some prisons. For jails where there are long pretrial confinements, appropriate AOD treatment also is a concern.

A full range of AOD services can be made available in larger jails. In particular, the jail setting is in several ways an appropriate setting for detoxification programs. Detoxification is a structured medical or social milieu in which an individual who is dependent on alcohol and/or other drugs is monitored during withdrawal from the acute physical and psychological effects of addiction. The jail setting provides the high level of structure and the opportunity for monitoring -- which sometimes involves 24-hour physician or nurse supervision -- that are necessary for detoxification. Detoxification is an essential first step in moving clients into AOD treatment, a step which can be completed in the jail setting even for those having long pretrial confinements or serving short sentences. In particular, detoxification and methadone programs, which address opiate addiction within the jail setting, can engage many individuals in treatment who might not otherwise seek it. Another TIP in this series, TIP 19:Detoxification from Alcohol and Other Drugs, (http://text.nlm.nih.gov/ftrs/dbaccess/tip19) describes safe regimens for detoxification in a variety of settings.

A medical unit is an essential jail component that includes outpatient care and inpatient hospitalization. Comprehensive services include health and medical programs for AOD-abusing individuals with mental illnesses and for patients with human immuno- deficiency virus (HIV), acquired immunodeficiency syndrome (AIDS), sexually transmitted diseases, or tuberculosis (TB). These services also include care for women's specialized needs. An enhanced voluntary program for HIV counseling and testing should be considered. Procedures should also be established to provide AOD treatment and other needed health-related services to inmates in protective custody or administrative segregation.

It must be noted here that it is an unfortunate reality that AOD abuse often can continue in jails. Therefore, another important component of a jail program is the monitoring of AOD use.

### Prison

A prison is an institution in which felony offenders are confined to terms of at least 1 year after sentencing. Prisons are operated by States and by the Federal Government. Prisons are classified as minimum-, medium-, or maximum-security facilities, based on the need for internal institutional safety and perimeter security. Each inmate is classified by severity of offense or other behavior and is usually assigned to a prison with a corresponding level of security.

Prison inmates are generally sentenced to a minimum of 1 or 2 years, depending on the State's laws. In some States, such as New York, California, Florida, and Illinois, prison sentences may be shorter than 1 year. Prisons, unlike jails, do not hold pretrial detainees. Because of the longer time periods involved for most offenders in prison, prison programs can have long-term components that are not options in jail programs. Historically, prisons have existed for punishment and incapacitation. It has only been in recent decades that policies have been implemented to emphasize habilitation and rehabilitation. Since many AOD-abusing individuals are sent to prison, a full range of AOD treatment services should be available in prisons.

A number of issues relate specifically to prisons and AOD treatment:

- Comprehensive pregnancy management for AOD abusers can enable a woman to carry her baby to term while incarcerated. Foster care services may be needed, and medical services should be available for both mother and child.
- Medical treatment for prisoners with chronic and communicable diseases, including TB and HIV/AIDS, should be available in prison.
- Psychiatric treatment for prisoners with mental illnesses should be offered. Pharmacotherapy for disorders such as bipolar disorder and major depression should be incorporated into these services.
- AOD abuse treatment should extend across institutional boundaries when offenders are transferred to different correctional facilities, and to the community after release.
- Special arrangements should be made for AOD treatment and healthcare services for offenders in protective custody and administrative segregation.
- Prerelease group programs and transitional community programming should be offered to all offenders, in particular to those who have been incarcerated for long periods of time.
- Education about HIV/AIDS and its risk factors should be a critical component of prison programs.
- Relapse prevention for AOD abusers should be a part of transitional programming.

The recognition of the overwhelming AOD problems of prison inmates has led to increasing acknowledgment of the needs of this population in prisons. In many cases, this need has created a dilemma. Should an AOD abuser be sent to prison, which may offer the best treatment opportunities, or be placed in a community setting, which may offer fewer opportunities? The answer to this dilemma is not to take treatment out of prisons, but to create treatment options in the community.

### Parole

Parole is a form of supervised release into the community following a term of incarceration. In most States, a parole board decides on a case-by-case basis which inmates to release from prison, when (at what point in the total sentence), and under what conditions. In the same way that a judge orders specific conditions of probation, the parole board orders specific conditions of parole. Failure to comply with the conditions can result in a motion to the board to revoke parole and return the parolee to prison. AOD abuse treatment and some of the intermediate sanctions described in Exhibit 4-1 are common conditions of parole release.

Exhibit 4-1 Forms of Intermediate Sanctions

- Means-based fines (also called "day" fines). The total amount of these fines is calibrated to both the severity of the crime and the discretionary income of the offender, with the calibration and calculation established by the court as a whole for all cases in which this type of fine is to be imposed. (This type of fine contrasts with traditional fines that are imposed at the discretion of the judge according to ranges set by the legislature for particular offenses.) Defendants with more income (and/or fewer familial obligations) pay a higher overall fine than those with lower incomes (and/or more obligations) for the same crime. This approach to setting the fine amount is typically coupled with expanded payment options and collection procedures that are tighter than usual.
- Community service. This is the performance by offenders of services or manual labor for government, private, or nonprofit organizations for a set number of hours with no payment. Community service can be arranged for individuals, case by case, or organized by corrections agencies as programs. For example, a group of offenders can serve as a work crew to clean highways or paint buildings.
- Restitution. Restitution is the payment by the offender of the costs of the victim's losses or injuries and/or damages to the victim. In some cases, payment is made to a general victim compensation fund; in others, especially where there is no identifiable victim, payment is made to the community as a whole (with the payment going to the municipal or State treasury).
- Special needs probation programs or caseloads. In these approaches to intermediate sanctions, officers with special training carry a restricted caseload. Typically, these approaches are used with offenders who have committed some categories of domestic violence, sex offenses, and driving under the influence, and with mentally ill, developmentally disabled, or substance-abusing offenders. Supervision in a specialized caseload may mean more intensive or more intrusive supervision than in routine caseloads, the provision of enhanced social and psychological services, and/or specific training or group activities, such as anger management classes or victim impact meetings.
- Outpatient or residential AOD abuse treatment centers. Both public and private treatment centers may be contracted to provide treatment to offenders, as described in this TIP.
- Day centers or residential centers for other types of treatment or training. These centers are established to provide services other than AOD abuse treatment. For example, a center may provide skills training to enhance offenders' employability.
- Intensive supervision probation. The level and types of supervision that are labeled intensive vary widely but usually involve closer supervision and greater reporting requirements than regular probation for offenders. This level can range from more than five contacts a week to fewer than four per month. Supervision usually entails other obligations (to attend school, have a job, participate in treatment, or the like). Intensive supervision parole has similar requirements and variations but is usually provided by parole agents to offenders who have completed a prison term and who are serving the balance of their sentences in the community.
- Day reporting centers. Under the terms of this intermediate sanction, offenders must report to the center for a certain number of hours each day, and/or report by phone throughout the day from a job or treatment site, as a means of monitoring and incapacitating them.
- Curfews or house arrest (with or without electronic monitoring). Offenders are restricted to their homes for various durations of time, ranging from all the time to all times except for work or treatment hours, with a few hours for recreation. Frequently, the curfew or house arrest is enforced by means of an electronic device worn by the offender which can alert corrections officials to his or her unauthorized absence from the house.
- Halfway houses or work release centers. Offenders are restricted to the facility but can leave for work, school, or treatment. The facility is in the community or attached to a jail or similar institution.
- Boot camps. Typically, a sentence to a boot camp (also called shock incarceration) is for a relatively short time (3 to 6 months). As the name implies, boot camps are characterized by intense regimentation, physical conditioning, manual labor, drill and ceremony, and military-style obedience. (Because boot camps are a form of incarceration, some in the criminal justice field reject their inclusion in the category of intermediate sanctions. Others include boot camps because placement in them is intended to take the place of a longer, traditional prison term.)

Not all States have parole as part of their sentencing laws. In California, Washington, and Minnesota, for example, an offender serves the term specified by the judge at the time of sentencing, minus time off for good behavior or program credits, if those are available in the State. In that case, the offender leaves prison under mandatory release and usually has no conditions on that release.

Parolees are supervised by parole officers, sometimes called parole agents. Parolees may have prohibitions on certain activities imposed by a paroling authority. Parole officers have the same authority with parolees as probation officers do with offenders on probation. The primary goal of parole is community reintegration after release from prison. The parole officer's role has evolved from supervisor to case manager, particularly for AOD-involved offenders.

The primary goal of the parole officer is to ensure community safety. Other goals are to help offenders in the transitional process of returning to society and to assist them in making appropriate choices from available community options. The parole officer often gradually reintroduces choices that the offender will need to make to become self-sufficient and adjust to the community. Specific objectives should be individualized for each offender. Thus, parole officers must be change agents. Sanctions should be used to assist treatment and habilitation outcomes and to encourage the offender to participate in community programs.

The location of the parole department within the State governmental structure has an effect on services. Parole departments are located in different divisions of government throughout the country. In one State, parole may be located within the corrections department and probation within the judiciary. Location translates into differences in communication, cooperation, interaction, and philosophical perspective. Location also can be related to service fragmentation and shifting departmental responsibility.

Although the parole board usually is the final arbiter, decisions involving parole should be made with input from the parole board and officers, the offender, and the treatment providers. A parole plan should be based on clear objectives so that all involved personnel know what is needed to reach the stated goals. This process also will assist parole officers in monitoring parolees and will help parolees know specifically what is expected of them.