# Appendix E—Field Reviewers

- Robert E. Anderson
- Director, Criminal Justice Programs
- National Association of State Alcohol and Drug Abuse Directors
- Washington, D.C.

- Robert Aukerman, M.S.W.
- Director, Alcohol and Drug Abuse Division
- Colorado Department of Health
- Denver, Colorado

- Catherine E. Bartels, M.Ed., C.C.D.C. III
- Director of Substance Abuse Programs
- South Dakota Department of Corrections
- Pierre, South Dakota

- Steven Belenko, Ph.D.
- Senior Research Fellow
- New York City Criminal Justice Agency
- New York, New York

- Steven A. Bocian
- Executive Director
- Governor's Office of Justice Administration
- Baltimore, Maryland

- Margaret K. Brooks, J.D.
- Consultant
- Montclair, New Jersey

- John A. Carver, J.D.
- Director
- District of Columbia Pretrial Service Agency
- Washington, D.C.

- Henry R. Cellini, Ph.D.
- President
- Training and Research Institute
- Albuquerque, New Mexico

- Frederick R. Chavaria, Ph.D.
- United States Probation and Parole Officer
- Substance Abuse and Contractor Specialist
- United States Probation Office
- Northern District of California
- San Francisco, California

- John H. Clark, M.D., M.P.H., C.C.H.P.
- Chief Medical Officer
- Los Angeles County Sheriff's Department
- Los Angeles, California

- Foster Cook, M.A., C.A.D.P.
- Assistant Professor
- Director, School of Medicine Department of Psychiatry Substance Abuse Programs
- University of Alabama at Birmingham
- Birmingham, Alabama

- Dorynne Czechowicz, M.D.
- Associate Director for Medical and Professional Affairs
- Medical Affairs Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Sammye Davies
- Program Specialist, Division on Alcoholism and Drug Abuse
- Nebraska Department of Public Institutions
- Lincoln, Nebraska

- Peter J. Delany, D.S.W.
- Social Science Analyst, National Institute on Drug Abuse
- Division of Clinical and Services Research Branch
- Rockville, Maryland

- David D. Dillingham, M.S.W.
- Correctional Program Specialist, Community Corrections Division
- National Institute of Corrections
- Washington, D.C.

- Wayne Dougherty, C.C.D.C. III
- Chemical Dependency Supervisor
- Springfield Correctional Facility
- Springfield, South Dakota

- Elizabeth Ann Downes, Ph.D.
- Organizational Development Consultant
- Shaening & Associates
- Santa Fe, New Mexico

- Parker Evatt
- Director
- South Carolina Department of Corrections
- Columbia, South Carolina

- Gary D. Field, Ph.D.
- Alcohol and Drug Program Manager
- Oregon Department of Corrections
- Salem, Oregon

- Michael M. Gimbel
- Director
- Baltimore County Office of Substance Abuse
- Towson, Maryland

- Ingrid D. Goldstrom, M.Sc.
- Social Science Analyst
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Addie Hailstorks, Esq.
- Acting Director, Defender Division
- National Legal Aid and Defender Association
- Washington, D.C.

- Merri L. Hankins, Esq.
- Director, National Drug Prosecution Center
- American Prosecutors Research Institute
- Alexandria, Virginia

- Melody Heaps
- President
- TASC, Inc.
- Chicago, Illinois

- D. Alan Henry
- Director
- The Pretrial Services Resource Center
- Washington, D.C.

- Paul D. Herman
- Chief State Supervisor
- Missouri Board of Probation and Parole
- Jefferson City, Missouri

- The Honorable Peggy Fulton Hora
- Judge
- Municipal Court
- Hayward, California

- Stephen J. Ingley
- Executive Director
- American Jail Association
- Hagerstown, Maryland

- Genita Johnson, M.D., M.P.H.
- Consultant
- Medford, Massachusetts

- Sylvia J. Johnson
- Chief Probation Officer
- Alamedo County Probation Department
- Oakland, California

- LaVerne Jones, Ph.D.
- Vice President, Corporate Development
- Health Services Technical Assistance -- Addiction Treatment Services, Inc.
- Detroit, Michigan

- Robert Kirchner, Ph.D.
- Chief, Program Evaluation
- Bureau of Justice Assistance
- U.S. Department of Justice
- Washington, D.C.

- Keith J. Lang, M.S.W.
- State Council Staff Coordinator
- Wisconsin Bureau of Substance Abuse Services
- Madison, Wisconsin

- Geoffrey Laredo, M.P.A.
- Senior Program Analyst, Office of Policy and Program Coordination
- Division of Planning and Policy Implementation
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Robert L. May, II
- Executive Director
- National Consortium of TASC Programs
- Washington, D.C.

- Ann McDiarmid, J.D.
- Correctional Program Specialist
- National Institute of Corrections
- Washington, D.C.

- John R. Miles, M.P.A.
- Substance Abuse Coordinator, HIV Prevention Among Drug Users Unit
- Division of STD/HIV Prevention
- Office of the Director
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Neal Miller
- Principal Associate
- Institute for Law and Justice
- Alexandria, Virginia

- Robert E. Myers, R.N., M.P.A., C.N.A.A., C.H.E.
- Director of Health Services
- Jackson County Detention Center
- Kansas City, Missouri

- Mickey M. Neel, I.C.A.D.C., N.C.A.C. II
- Substance Abuse Unit Administrator
- Texas Department of Criminal Justice
- Community Justice Assistance Division
- Austin, Texas

- Cassandra F. Newkirk, M.D.
- Deputy Commission of Offender Services
- Georgia Department of Corrections
- Atlanta, Georgia

- Ernest Packebush
- Superintendent, Pine Lodge Pre-Release
- Washington Department of Corrections
- Medical Lake, Washington

- Nicholas Pastore
- Chief of Police
- New Haven Department of Police Service
- New Haven, Connecticut

- Roger H. Peters, Ph.D.
- Associate Professor
- Department of Mental Health Law and Policy
- Florida Mental Health Institute
- University of South Florida
- Tampa, Florida

- William H. Pimentel, M.A.
- Assistant Director
- Rhode Island Department of Substance Abuse
- Rhode Island Medical Center
- Cranston, Rhode Island

- The Honorable Dalton A. Roberson, Sr.
- Chief Judge
- Detroit Recorder's Court
- Detroit, Michigan

- Virginia S. Ryan, Ph.D.
- Principal Investigator
- Self Help Addiction Rehabilitation
- Detroit, Michigan

- The Honorable Linda Stout Saunders, J.D.
- Acting Justice
- Concord District Court Hearings Officer
- New Hampshire Division of Mental Health and Developmental Services
- Hopkinton, New Hampshire

- Mary Ann Shaening, Ph.D.
- Director
- Shaening & Associates
- Santa Fe, New Mexico

- Steven J. Shapiro
- Public Health Advisor, Criminal Justice Systems Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Phillip Showstead, L.I.C.S.W.
- Executive Director
- South King County Drug and Alcohol Recovery Centers
- Burien, Washington

- Rose Soo Hoo, M.B.A., M.S.W.
- Administrator, King County North Rehabilitation Facility
- Division of Alcohol and Substance Abuse Services
- Seattle, Washington

- Gilbert Sudbeck, C.C.D.C. III
- Director, Division of Alcohol and Drug Abuse
- South Dakota Department of Human Services
- Pierre, South Dakota

- Wayne Thacker
- Team Leader, Community Health Initiative
- Center for Public Policy
- Virginia Commonwealth University
- Richmond, Virginia

- Kim Marie Thorburn, M.D.
- Health Care Division Administrator
- Hawaii Department of Public Safety
- Honolulu, Hawaii

- David S. Timken, Ph.D.
- Research Scientist and Clinical Consultant, Alcohol and Drug Abuse Division
- Colorado Department of Human Services
- Denver, Colorado

- Stephen K. Valle, Sc.D., M.B.A., N.C.A.C.
- President and Chief Executive Officer
- Right Turn, Inc.
- Lynn, Massachusetts

- Patricia L. Watson, M.Ed.
- President
- Corrections Alternatives and Concepts
- Smyrna, Delaware

- Mary E. West, Ed.D.
- Supervisor II, Correctional Program Specialist
- Denver Women's Correctional Facility
- Denver, Colorado

- William R. Woodward, M.P.A.
- Director, Division of Criminal Justice
- Colorado Department of Public Safety
- Denver, Colorado

- Malcolm Young
- Executive Director
- The Sentencing Project
- Washington, D.C.

- John K. Zachariah
- Chief Probation Officer, Court of Common Pleas
- Cuyahoga County Juvenile Court
- Cleveland, Ohio