# Appendix D—Federal Resource Panel

- Robert E. Anderson
- Director, Criminal Justice Programs
- National Association of State Alcohol and Drug Abuse Directors
- Washington, D.C.

- Robert Aukerman, M.S.W.
- Director, Alcohol and Drug Abuse Division
- Colorado Department of Human Services
- Denver, Colorado

- Duiona R. Baker, M.P.H.
- Public Health Advisor, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Virginia Brooks Baldau
- Director, Research Applications and Training Division
- National Institute of Justice
- U.S. Department of Justice
- Washington, D.C.

- Steve Bocian
- Executive Director
- Governor's Office of Justice Administration
- Baltimore, Maryland

- Jim Brennan
- Staff Associate
- National Association of Social Workers
- Washington, D.C.

- Fulton Caldwell, Ph.D.
- Health Scientist Administrator
- National Institute on Alcohol Abuse and Alcoholism
- Bethesda, Maryland

- Diane Canova, J.D.
- Executive Director
- Therapeutic Communities of America
- Arlington, Virginia

- Judge Elbridge Coochise
- President, National American Indian Court Judge Association
- Northwest Intertribal Court System
- Edmonds, Washington

- Mark Cunniff
- Executive Director
- National Association of Criminal Justice Planners
- Washington, D.C.

- Dorynne Czechowicz, M.D.
- Associate Director, Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Peter Delany, D.S.W.
- Social Science Analyst, Services Research Branch
- Division of Clinical and Services Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida

- Ingrid D. Goldstrom, M.Sc.
- Social Science Analyst, Statistical Research Branch
- Center for Mental Health Services
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- John Gregrich
- Senior Policy Analyst
- Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.

- Carl Hampton
- Associate Director for Special Projects
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Harry W. Haverkos, M.D.
- Director, Office on AIDS
- National Institute on Drug Abuse
- Rockville, Maryland

- James A. Inciardi, Ph.D.
- Professor and Director
- Center for Drug and Alcohol Studies
- University of Delaware
- Newark, Delaware

- Nolan Jones, Ph.D.
- Director of Justice and Public Safety
- National Governor's Association
- Washington, D.C.

- Sandra H. Kerr
- Public Health Analyst, Division of STD/HIV Prevention
- Behavioral and Prevention Research Branch
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Charlene S. Lewis, Ph.D.
- Chief, Program Evaluation Branch
- Office of Scientific Analysis and Evaluation
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Anna Marsh, Ph.D.
- Associate Director for Evaluation
- Office of Applied Studies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Sue Martone
- Legislative Analyst, Division of Legislation and External Affairs
- Office of the Administrator
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Ann McDiarmid, J.D.
- Correctional Program Specialist
- National Institute of Corrections
- Washington, D.C.

- Peggy McGarry
- Senior Associate
- Center for Effective Public Policy
- Washington, D.C.

- Roberta Messalle
- Public Health Analyst, Office of Policy and Coordination
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Marilyn Rice, M.A., M.P.H., C.H.E.S.
- Deputy Director, National Resource Center for the Prevention of Perinatal Abuse of Alcohol and Other Drugs
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Barbara Roberts, Ph.D.
- Senior Policy Analyst, Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.

- Marilyn McCoy Roberts
- Senior Staff Associate
- National Center for State Courts
- Arlington, Virginia

- Gayle Saunders
- Program Assistant, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Steven J. Shapiro
- Public Health Advisor, Criminal Justice Systems Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Brenda Smith, Esq.
- Senior Council/Economic Security
- National Women's Law Center
- Washington, D.C.

- Philip Toelkes
- Program Manager
- State Justice Institute
- Alexandria, Virginia

- Stephen K. Valle, Sc.D., M.B.A., N.C.A.C.
- National Association of Alcoholism and Drug Abuse Counselors
- Lynn, Massachusetts

- Gerald L. Vigdal, M.S.W., B.C.D. - Chair
- Director, Office of Drug Programs
- Wisconsin Department of Corrections
- Madison, Wisconsin

- Ellen Weber, Esq.
- Legal Counsel
- Legal Action Center
- Washington, D.C.

- Beth Weinman
- National Drug Abuse Coordinator, Psychology Branch
- Federal Bureau of Prisons
- Washington, D.C.

- Cecelia Willis, M.D.
- National Black Alcoholism Council
- Washington, D.C.

- John K. Zachariah
- Regional Administrator, American Correctional Association
- Laurel, Maryland