# Appendix B—CSAT Criminal Justice Treatment Planning Chart

The Criminal Justice Treatment Planning Chart is a 3 1/2 foot fold-out chart suitable for display. The reverse side of the chart contains a glossary of the terms used in the chart. There was no effective way to present this chart in electronic format.

A copy of the entire TIP containing the chart can be ordered from the National Clearinghouse of Drug and Alcohol Information (NCADI). The order number for TIP 17: Planning for Alcohol and Other Drug Abuse Treatment for Adults in the Criminal Justice System is BKD165. It is free and can be ordered from NCADI's electronic catalog at http://www.health.org/pubs/catalog/ordering.htm or by calling 1-800-729-6686.