# Appendix A -- Bibliography

Abeles, H., Feibes, H., Mandel, E., and Girard, J.A. The large city prison: a reservoir of tuberculosis. American Review of Respiratory Disease. 1970;101:706-709.
Anglin, M.D., Brecht, M.L., and Maddahian, E. Pretreatment characteristics and treatment performance of legally coerced versus voluntary methadone maintenance admissions. Criminology. 1989;27:537-557.
Anglin, M.D., and Hser, Y.I. Treatment of drug abuse. In: Tonry, M., and Wilson, J.Q., eds. Drugs and Crime. Chicago: University of Chicago Press. 1990:pp. 393-460.
Anglin, M.D., and Maugh, T.H. Ensuring success in interventions with drug-using offenders. Annals of the American Academy of Political and Social Sciences. 1992;521:66-90.
Argyris, C. Intervention Theory and Method: A Behavioral Science View. Reading, Massachusetts: Addison-Wesley. 1973.
Aspler, R., and Harding, W.M. Cost-effectiveness analysis of drug abuse treatment: current status and recommendations for future research. In: Background Papers on Drug Abuse Financing and Services Research. NIDA Drug Abuse Services Research Series. DHHS Publication No. (ADM) 91-1777. Rockville, Maryland: National Institute on Drug Abuse. 1991:pp. 58-81.
Ball, J., Carty, E., Bond, H., Myers, C., et al. The reduction of intravenous heroin use, non-opiate use, and crime during methadone maintenance treatment: further findings. In: Harris, L.S., ed. Problems of Drug Dependence, 1987: Proceedings of the 49th Annual Scientific Meeting, The Committee on Problems of Drug Dependence, Inc. NIDA Research Monograph 81. DHHS Publication No. (ADM) 88-1564. Rockville, Maryland: National Institute on Drug Abuse. 1987:pp. 224-230.
Bureau of Justice Statistics. Drugs and Crime Facts, 1992. Washington, D.C.: U.S. Department of Justice. 1993a.
Bureau of Justice Statistics. Prisoners in 1992. Washington, D.C.: U.S. Department of Justice. 1993b.
Bureau of Justice Statistics. Sourcebook of Criminal Justice Statistics, 1993. U.S. Department of Justice. 1994.
Bureau of Justice Statistics. Survey of Inmates in State Prisons, 1991. Washington, D.C.: U.S. Department of Justice. 1993c.
California Department of Alcohol and Drug Programs. Evaluating Recovery Services: The California Drug and Alcohol Assessment (CALDATA). Sacramento: California Department of Alcohol and Drug Programs. 1994.
Center for Substance Abuse Prevention. Prevention Primer: An Encyclopedia of Alcohol, Tobacco, and Other Drug Prevention Terms. DHHS Publication No. (SMA) 94-2060. Rockville, Maryland: Center for Substance Abuse Prevention. 1993.
Center for Substance Abuse Treatment. TIE Communique. Special Issue: Forging links to treat the substance-abusing offender. Spring. 1993.
Centers for Disease Control and Prevention. Prevention and control of tuberculosis in correctional institutions: recommendations of the Advisory Committee for the Elimination of Tuberculosis. Morbidity and Mortality Weekly Report. 1989;38:313-320, 325.
Chiles, J.A., Von Cleve, E., Jemelka, R.P., and Trupin, E.W. Substance abuse and psychiatric disorders in prison inmates. Hospital and Community Psychiatry. 1990;41:1132-1134.
Cohen, J. Statistical Power Analysis for the Behavioral Sciences. New York: Academic Press. 1977.
Cook, L.F., and Weinman, B.A. Treatment alternatives to street crime. In: Leukefeld, C.G., and Tims, F.M., eds. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. NIDA Research Monograph No. 86. Rockville, Maryland: National Institute on Drug Abuse. 1988:pp. 99-105.
Cote, G., and Hodgins, S. Co-occurring mental disorders among criminal offenders. Bulletin of the American Academy of Psychiatry and Law. 1990;18:271-281.
De Leon, G. Legal pressure in therapeutic communities. In: Leukefeld, C.G., and Tims, F.M., eds. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. NIDA Research Monograph No. 86. Rockville, Maryland: National Institute on Drug Abuse. 1988:pp. 160-177.
Dennis, M.L. Design, management, and analysis of randomly controlled trials in community-based settings. In: Wholey, J.S., Hatry, H., and Newcomer, K., eds. Handbook of Practical Program Evaluation. San Francisco: Jossey-Bass. 1993.
Edna McConnell Clark Foundation. Americans Behind Bars. New York. 1993.
Falkin, G.P., Wayson, B.L., Wexler, H.K., and Lipton, D.S. Treating Prisoners for Drug Abuse: An Implementation Study of Six Prison Programs. New York: Narcotic and Drug Research, Inc. 1991.
Field, G. The Cornerstone program: a client outcome study. Federal Probation. 1985;49:50-55.
Field, G. The effects of intensive treatment on reducing the criminal recidivism of addicted offenders. Federal Probation. 1989;53:51-56.
General Accounting Office. Drug Treatment: State Prisons Face Challenges Providing Services. Washington, D.C.: General Accounting Office. 1991.
Gerstein, D.R., and Harwood, H.J. Institute of Medicine Committee for the Substance Abuse Coverage Study. Treating Drug Problems, Volume 1: A Study of the Evolution, Effectiveness and Financing of Public and Private Drug Treatment Systems. Washington, D.C.: National Academy Press. 1990.
Glaser, J.B., and Greifinger, R.B. Correctional health care: a public health opportunity. Annals of Internal Medicine. 1993;118:139.
Hammett, T.M., Harold, L., and Epstein, J. Tuberculosis in Correctional Facilities. Washington, D.C.: National Institute of Justice, January. 1994.
Hammett, T.M., Harold, L., Gross, M., and Epstein, J. Update 1992: HIV/AIDS in Correctional Facilities. Washington, D.C.: National Institute of Justice. 1993.
Hartjen, C.A., Mitchell, S.M., and Washburne, N.F. Sentencing therapy: some legal, ethical, and practical issues. Journal of Offender Counseling Services and Rehabilitation. 1982;6:21-39.
Harwood, H.J., Hubbard, R.L., Collins, J.J., and Rachal, J.V. The costs of crime and the benefits of drug abuse treatment: a cost-benefit analysis using TOPS data. In: Leukefeld, C.G., and Tims, F.M., eds. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. NIDA Monograph Series 86. Rockville, Maryland: National Institute on Drug Abuse. 1988:pp. 209-234.
Holmes, S.A. The boom in jails is locking up lots of loot. New York Times Sec. 4, November 6. 1994a.
Holmes, S.A. Rank of inmates reach one million in a 2-decade rise. New York Times. October 27. 1994b.
Hubbard, R.L., Marsden, M.E., Cavanaugh, E.R., Rachal, J.V., et al. The role of drug abuse treatment in limiting the spread of AIDS. Review of Infectious Diseases. 1988;10:377-384.
Hubbard, R.L., Marsden, M.E., Rachal, J.V., Harwood, H.J., et al. Drug Abuse Treatment: A National Study of Effectiveness. Chapel Hill: University of North Carolina Press. 1989.
Inciardi, J.A., and McBride, D.C. Treatment Alternatives to Street Crime (TASC): History, Experiences, and Issues. Rockville, Maryland: National Institute on Drug Abuse. 1991.
Katz, J., and Plunkett, R.E. Prevalence of clinically significant pulmonary tuberculosis among inmates of New York State penal institutions. American Review of Tuberculosis. 1950;61:51-56.
Klein, M.W., and Van Dusen, K.T., eds. Handbook of Criminal Justice Evaluation. Beverly Hills, California: Sage Publications. 1980.
Leukefeld, C.G., and Tims, F.M. Compulsory treatment for drug abuse. International Journal of the Addictions. 1990;25:621-640.
Leukefeld, C.G., and Tims, F.M. Compulsory Treatment of Drug Abuse: Research and Clinical Practice. NIDA Research Monograph No. 86. Rockville, Maryland: National Institute on Drug Abuse. 1988.
Lipsey, M.W. Design Sensitivity: Statistical Power for Experimental Research. Newbury Park, California: Sage Publications. 1990.
Lopez, F. Confidentiality of Patient Records for Alcohol and Other Drug Treatment. Technical Assistance Publication Series 13. Rockville, Maryland: Center for Substance Abuse Treatment. 1994.
MacKenzie, D.L., and Souryal, C. Multisite Evaluation of Shock Incarceration. Washington, D.C.: National Institute of Justice, November. 1994.
Maddux, J.F., and Desmond, D.P. Relapse and recovery in substance abuse careers. In: Tims, F.M., and Leukefeld, C.G., eds. Relapse and Recovery in Drug Abuse. NIDA Research Monograph 72. Rockville, Maryland: National Institute on Drug Abuse. 1986:pp. 49-71.
McGlothlin, W.H., and Anglin, M.D. Shutting off methadone: costs and benefits. Archives of General Psychiatry. 1981;38:885-892.
McLellan, A.T., Luborsky, L., Woody, G.E., O'Brien, C.P., et al. Increased effectiveness of substance abuse treatment: a prospective study of patient-treatment "matching.". Journal of Nervous and Mental Disorders. 1983;171:597-605.
Meier, K.J. Race and the war on drugs: America's dirty little secret. Policy Currents. 1992;2:2.
Mieczkowski, T. The accuracy of self-reported drug use: an evaluation and analysis of new data. In: Weisheit, R., ed. Drugs, Crime, and the Criminal Justice System. Cincinnati: Anderson. 1990.
Mirin, S.M., Weiss, R.D., Michael, J., and Griffin, M.L. Psychopathology in substance abusers: diagnosis and treatment. American Journal of Drug and Alcohol Abuse. 1988;14:139-157.
Nurco, D.N., Ball, J.C., Shaffer, J.W., and Hanlon, T.E. The criminality of narcotic addicts. Journal of Nervous and Mental Disease. 1985;173:94-102.
Orsagh, T., and Marsden, M.E. What works when: rational-choice theory and offender rehabilitation. Journal of Criminal Justice. 1985;13:269-277.
Peters, R.H., Kearns, W.D., Murrin, M.R., and Dolente, A.S. Psychopathology and mental health needs among drug-involved inmates. Journal of Prison and Jail Health. 1992a;11:3-25.
Peters, R.H., May, R.L., and Kearns, W.D. Drug treatment in jails: results of a nationwide survey. Journal of Criminal Justice. 1992b;20:283-295.
Petersilia, J. Expanding Options for Criminal Sentencing. RAND Report R-3544-EMC. Santa Monica, California: RAND Corp. 1987.
Petersilia, J., and Turner, S. Comparing intensive and regular supervision for high-risk probationers: early results from an experiment in California. Crime and Delinquency. 1990;36:87-111.
Petersilia, J., Turner, S., and Deschenes, E.P. Intensive supervision programs for drug offenders. In: Byrne, J.M., Lurigio, A.J., and Petersilia, J., eds. Smart Sentencing: The Emergence of Intermediate Sanctions. Newbury Park, California: Sage Publications. 1992.
Platt, J.J., Buhringer, G., Kaplan, C.D., Brown, B.S., et al. The prospects and limitations of compulsory treatment for drug addiction. Journal of Drug Issues. 1988;18:505-525.
Regier, D., Farmer, M.F., Rae, D.S., Locke, B., et al. Comorbidity of mental disorders with alcohol and other drug abuse: results from the Epidemiological Catchment Area (ECA) study. Journal of the American Medical Association. 1990;264:2511-2518.
Rossi, P.H. The iron law of evaluation and other metallic rules. Research in Social Problems and Public Policy. 1987;4:3-20.
Rouse, B., Kozel, N., and Richards, L., eds. Self-Report Methods of Estimating Drug Use: Meeting Challenges to Validity. NIDA Research Monograph No. 57. Rockville, Maryland: National Institute on Drug Abuse. 1985.
Salmon, R.W., and Salmon, R.J. The role of coercion in rehabilitation of drug abusers. International Journal of the Addictions. 1983;18:9-21.
Sells, S.B. Treatment and rehabilitation. In: Kadish, S.H., ed. Encyclopedia of Crime and Justice, Vol. 2. New York: Free Press. 1983.
Sells, S.B., and Simpson, D.D., eds. The Effectiveness of Drug Abuse Treatment. Vol. 3: Further Studies of Drug Users, Treatment Typologies, and Assessments of Outcomes During Treatment in the DARP. Cambridge, Massachusetts: Ballinger. 1976.
Senay, E.C. Methadone maintenance. In: Treatment of Psychiatric Disorders: A Task Force Report of the American Psychiatric Association. Washington, D.C.: American Psychiatric Association. 1989.
Shaffer, J.W., Nurco, D.N., Kinlock, T.W., Duszynski, T.R., et al. The relationship of pre-addiction characteristics to the types and amounts of crimes committed by narcotic addicts. International Journal of the Addictions. 1987;22:153-165.
Smith, B.V. Special needs of women in the criminal justice system. Center for Substance Abuse Treatment TIE Communique, Spring. 1993:pp. 31-32.
Tims, F.M., and Leukefeld, C.G., eds. Relapse and Recovery in Drug Abuse. NIDA Research Monograph 72. Rockville, Maryland: National Institute on Drug Abuse. 1986.
Turner, S., Petersilia, J., and Deschenes, E.P. Evaluating intensive supervision probation parole (ISP) for drug offenders. Crime and Delinquency. 1992;38:539-556.
Volpicelli, J.R., Alterman, A.I., Hayashida, M., and O'Brien, C.P. Naltrexone in the treatment of alcohol dependence. Archives of General Psychiatry. 1992;49:876-880.
Weis, J.G. Issues in the measurement of criminal careers. In: Blumstein, A., Cohen, J., Roth, J.A., and Visher, C.A., eds. Criminal Careers and "Career Criminals," Vol 2. Washington, D.C.: National Academy Press. 1986.
Wexler, H.K., Falkin, G.P., and Lipton, D.S. Outcome evaluation of a prison therapeutic community for substance abuse treatment. Criminal Justice and Behavior. 1990;17:71-92.
Wish, E., and Gropper, B. Drug testing by the criminal justice system: methods and applications. In: Tonry, M., and Wilson, J., eds. Drugs and Crime. Chicago: University of Chicago Press. 1990:pp. 321-391.
Wolber, G.J., Carne, W.F., and Alexander, R. The validity of self-reported abstinence and quality sobriety following chemical dependency treatment. International Journal of the Addictions. 1990;25:495-513.
Yen, M. After shock. Washington Post, November 20. 1994.

### Other Authorities

Confidentiality of Alcohol and Drug Abuse Patient Records, 42 C.F.R. Part 2.
Public Health Law, 42 U.S.C. §290 Comprehensive Alcohol and Alcoholism Prevention Treatment and Rehabilitation Act of 1970; Drug Abuse Prevention, Treatment and Rehabilitation Act.
Hasenie v. United States, 541 F. Supp. 999 (D. Md. 1982).
Tarasoff v. Regents of the University of California, 17 Cal. 3d 425 (1976).