# A Note to Readers

This Treatment Improvement Protocol (TIP) has been written for a wide-ranging audience, including State alcohol and other drug (AOD) authorities; administrators and staff of AOD abuse treatment programs; emergency department and hospital personnel, such as physicians, nurses, and social workers; public health authorities; and healthcare policymakers. Some readers may find that certain chapters contain material with which they are highly familiar. The chapters are described below so that readers can select those of primary interest.

Chapter 1 Introduction describes the significant role that substance use, abuse, and dependence play in traumatic injury and reinjury and presents statistics and other evidence of the broad scope of the problem. While this chapter will be informative to all audiences, it is particularly targeted to policymakers to bring attention to the social and financial costs of this problem.

Chapter 2 Trauma Patients describes hospitalized trauma patients, including the types of injuries they sustain and their treatment and rehabilitation. Physicians, nurses, and other hospital personnel will be highly familiar with the material presented. The chapter is primarily targeted to AOD abuse treatment providers.

Chapter 3 Effects of Alcohol and Other Drugs on Trauma Patients describes the effects of acute and chronic AOD use on the management of trauma patients, both in the emergency phase of treatment and later in the subacute and rehabilitation phases. Insofar as the chapter provides strong evidence for the value of ascertaining patients' AOD status via screening and assessment and making AOD interventions when appropriate, the chapter will be informative to all audiences.

Chapter 4 Screening and Assessment describes the processes of screening and assessment for AOD use, abuse, and dependence. Several widely used screening questionnaires are described. The chapter is targeted primarily to hospital personnel and administrators who may be considering establishing a screening program. Most AOD treatment providers will be very familiar with these processes. However, the chapter also reviews research and current thinking on the effectiveness of brief AOD interventions and presents guidelines for making such interventions in the hospital setting. This information will be of interest to all care providers.

Chapter 5 Cost-Benefit Issues Affecting Implementation of Screening discusses the benefits of screening of hospitalized trauma patients and the financial costs associated with implementing a screening program. The chapter will be of most interest to hospital administrators and policymakers.

Chapter 6 Legal and Ethical Concerns explores ethical issues concerning protection of patients' confidentiality and the use of screening. A case example illustrates these concerns. The chapter is targeted primarily to care providers in the hospital setting.

Chapter 7 Recordkeeping and Quality Improvement addresses the issue of handling records to protect patients' confidentiality. The chapter explores ways in which outcomes can be defined and measured in order to ensure the continued quality improvement of the screening and assessment program. The chapter is targeted primarily to care providers in the hospital setting.