# Consensus Panel

Chair
- Peter O. Rostenberg, M.D.
- Co-Chair, Trauma Committee
- American Society of Addiction Medicine
- Internal Medicine, Addiction Medicine
- New Fairfield, Connecticut
- Allan Graham, M.D., F.A.C.P.
- Medical Director
- Founders Hall
- St. Johnsbury, Vermont
- John Loiselle, M.D.
- Assistant Professor of Pediatric
- Emergency Medicine
- Medical College of Pennsylvania
- St. Christopher's Hospital for Children
- Philadelphia, Pennsylvania
- Marilyn Sawyer Sommers, R.N., Ph.D.
- Assistant Professor, College of Nursing and Health
- University of Cincinnati
- Cincinnati, Ohio

Workgroup Members
- John Ambre, M.D., Ph.D.
- Director, Department of Toxicology and Drug Abuse
- American Medical Association
- Chicago, Illinois
- Margaret Kent Brooks, J.D.
- Consultant
- Montclair, New Jersey
- Andrew DiBartolomeo, M.D., M.B.A., F.A.C.E.P.
- Medical Director
- Apple Creek Developmental Center
- Apple Creek, Ohio
- Roman Frankel, N.C.A.C. II, C.E.A.P.
- President/Executive Director
- New Start Inc.
- West Bloomfield, Michigan
- Elizabeth Garcia, C.M.S.W.
- Director of Managed Care
- Pinal Gila Behavioral Health Association
- Apache Junction, Arizona
- Larry M. Gentilello, M.D.
- Assistant Professor, Department of Surgery
- Harborview Medical Center
- Seattle, Washington
- James N. Heckler, M.S., M.B.A.
- Coordinator, Healthcare Intervention Services Demonstration
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York
- Christine L. Kasser, M.D.
- Medical Director, Baptist Recovery Center
- Baptist Memorial Hospital
- Memphis, Tennessee
- Thomas W. Kozlowski, A.C.S.W.
- Associate Director, Office of Mental Health Accreditation Services
- Joint Commission on Accreditation of Healthcare Organizations
- Oakbrook Terrace, Illinois
- Rita J. Seeds, L.M.S.W.
- Program Manager, Long-Term Care and Restorative Services Division
- New Mexico Department of Health
- Santa Fe, New Mexico
- Dena J. Seiden, Ph.D.
- Medical Ethicist
- Medical Ethics Consulting Services
- New York, New York
- Francis R. Sparadeo, Ph.D.
- Director of Substance Abuse Services
- Department of Psychiatry
- Rhode Island Hospital
- Providence, Rhode Island
- Herbert L. Thornhill, M.D.
- Director, Department of Rehabilitation Medicine
- Harlem Hospital Center
- New York, New York