# Chapter 4—Screening and Assessment

In this chapter, the processes of screening and assessment as they might be implemented in a Level 1 trauma center or community hospital are outlined. The consensus panel's recommendations about who should be screened and when patients should be screened are presented, and issues that the panel considered in making these recommendations are discussed.

Various laboratory tests for detecting alcohol and other drugs (AODs) in blood and urine are described. Brief questionnaires and other screening questions should be used to supplement results of laboratory tests. This chapter reviews several brief instruments that institutions may consider for use in an AOD screening program.

In some cases, a biopsychosocial AOD assessment of the trauma patient is appropriate, if the patient consents. The chapter offers guidelines for conducting an AOD assessment, including suggestions about which patients to assess and who should conduct the assessment. Components of an effective AOD assessment are described.

Trauma patients are a unique population. Compared with other persons with substance dependence, persons injured in substance-related mishaps may have reached a point in their lives where they may be likely to reflect on the relationship between their addiction and its consequences. They may be motivated and ready for treatment. The opportunity for intervention with these individuals should not be overlooked. It is beyond the scope of this Treatment Improvement Protocol (TIP) to describe the many modes of AOD treatment. However, this chapter includes a discussion of brief AOD interventions that can be conducted in a hospital setting. Brief interventions have been shown to be surprisingly effective in motivating patients to reduce AOD use and engaging them in treatment.

## Level 1 Trauma: Screening and Assessment

Studies of samples of hospitalized trauma patients have shown that from 20 to 86 percent test positive for alcohol or other drugs (Sloan et al., 1989). For example, analysis of data from 4,063 trauma patients in six regional trauma centers in the United States found that 40.2 percent had a positive blood alcohol concentration (BAC) on admission (Soderstrom et al., 1992). Toxicology screening of blood and urine in 936 patients at one university trauma center found 65 percent were positive for one or more drugs (Bailey, 1990). And a third study of 177 patients with a diagnosis of multiple trauma found that 72 percent had positive toxicology screens for AODs (Clark and Harchelroad, 1991).

Screening for alcohol and other drug use is a critical component of hospital management of the patient with traumatic injuries. As described in Chapter 3, screening has immediate benefits for medical management of trauma patients; for example, results of screening tests help caregivers understand the cause of a patient's altered mental status. In addition, screening is the basis for identifying persons at risk of reinjury because of underlying substance use problems.

Toxicology screening of blood and urine in 936 patients at one university trauma center found 65 percent were positive for one or more drugs.

## Definitions and Overview

To understand how the screening process can function effectively, some basic definitions are helpful.

Screening is the application of a simple test to a group of persons for the purpose of identifying a subgroup with a certain condition. In many communities, various healthcare organizations sponsor programs to screen for particular illnesses, including breast and colorectal cancer and hypertension, among at-risk groups.

is the application of a simple test to a group of persons for the purpose of identifying a subgroup with a certain condition.

The purpose of screening hospitalized trauma patients for AOD use is not to place every patient in AOD treatment, but to provide information necessary for appropriate medical management of trauma patients, both in the acute phase of care and in rehabilitation. Another important purpose of screening in this patient group is to identify those whose use of alcohol and other drugs may have contributed to their injuries. Those who may have underlying substance abuse or dependence or who may be at risk of developing these disorders can then be referred to appropriate treatment.

Different types of AOD screening tools are used; most frequently these are laboratory tests (usually of the blood or urine) or brief oral or written questionnaires. Self-report questionnaires and short structured interviews are also used.

The consensus panel that developed this TIP recommends administration of laboratory screening tests such as blood alcohol concentrations and urine drug screens as the basis of an AOD screening program to be implemented among hospitalized trauma patients. However, the panel agreed that laboratory tests alone are not adequate to screen for underlying substance use disorders. Laboratory screening tests simply detect the presence or absence of a substance in body fluids and thus indicate recent use. Effective screening depends on interpretation of these results with other information about frequency and pattern of AOD use. Simple screening instruments—either self-administered questionnaires or a set of questions to ask the patient -- play an important role in the AOD screening process and provide useful information for helping clinicians interpret the results of laboratory screening tests and make decisions about referral for AOD assessment.

The Institute of Medicine (1990) has recommended that questions about alcohol use be included among routine lifestyle assessment questions asked of all persons presenting for care in a medical setting. Valuable details about a patient's possible AOD problems can be gained from routine behavioral questions about weight, diet, exercise, and tobacco use and direct observations of the patient by healthcare staff. In addition, patients' charts can be scanned for evidence of a history of substance use problems. Family members may also provide information about a patient's substance use problems, but the family must be approached in a manner that protects the patient's confidentiality (see Chapter 6).

All screening tests should be optimized for sensitivity. A test's sensitivity indicates how well it is able to detect the target condition in a given population when it is present. As an instrument's sensitivity increases, so do the number of false positives it detects. The test should, to the best extent possible, be used to identify all (or the vast majority) of those with the defined condition (AOD use). It is understood that the philosophy of casting a wide net will inevitably identify a number of false positives.

The specificity of a test refers to its ability to identify persons who do not have the disorder. Both sensitivity and specificity should be considered in selecting or developing a screening instrument.

Positive screening results should be addressed. The patient's attending physician should determine the most appropriate way to address the results. In many cases, an AOD assessment is appropriate if the patient consents. AOD assessment is the process by which the results of screening tests are confirmed or refuted. Assessment is a comprehensive biopsychosocial process incorporating a range of evaluation procedures and techniques. More specific elements of assessment are discussed later in this chapter.

The

The AOD assessment process eliminates false positive screening results. Once the positive results are confirmed, the assessment then determines the severity of the AOD problem. The information gained in the AOD assessment will be used to provide data to help determine appropriate patient management. As described below, the patient has an active role in the AOD assessment process, both in appraising the severity of the problem and in planning treatment.

### Who Should Be Screened?

#### Alcohol

The panel recommends that BACs be obtained routinely for all hospitalized trauma patients aged 14 and over at the time of admission to the emergency room or trauma center. This procedure is needed because of the high prevalence of AOD use and dependence in this population and the associated higher risk of injury. BACs for patients under age 14 may be obtained if there is suspicion of alcohol use. Clinical decisions about screening patients under age 14 should take into account local patterns of alcohol use. Many parents of younger children may object to such screening.

Obtaining a BAC improves differential diagnosis and immediate patient management by indicating the need for further diagnostic testing in regard to the injury, or the potential need for alcohol withdrawal management. The BAC is also an effective screening tool for identifying patients who need further assessment to determine the need for counseling regarding their drinking.

The panel recommends that patients with BACs above 20 mg/dl (.02 percent) be considered for further AOD assessment.

#### Other Drugs

The panel recommends that urine drug screens also be obtained routinely from all hospitalized trauma patients aged 14 and over at the time of admission. Similarly, screens should be considered for persons under age 14, if there is suspicion of use. Results may be helpful in making a differential diagnosis, managing patients with withdrawal syndromes, and accurately interpreting vital signs. Results of drug screens may help in understanding other effects that may complicate the clinical picture, such as the use of multiple prescription drugs by elderly persons. Urine drug screens can also be effective in identifying patients who need further assessment to determine if there is a need for counseling or referral for treatment for a drug use disorder.

Urine drug screens can determine the presence of sedative-hypnotics, cocaine, opiates, and cannabis. However, additional tests, such as those for phencyclidine (PCP), methadone, and lysergic acid diethylamide (LSD), may be done, depending on the patient's presentation and on the clinician's knowledge of drug use patterns in the community.

The use of these screens should occur in a context of heightened sensitivity about the need to protect the patient's privacy and maintain confidentiality. This issue is discussed in Chapter 6 of this TIP.

Many issues must be considered when screening and assessing adolescents for alcohol and other drug use. Another Treatment Improvement Protocol in this series, Screening and Assessment of Alcohol- and Other Drug-Abusing Adolescents, provides detailed information about conducting screening and assessment of adolescents; several instruments specifically designed for use with this patient group are reviewed.

The panel recommends that blood alcohol concentrations and urine drug screens be obtained routinely for all hospitalized trauma patients aged 14 and over at the time of admission to the emergency room or trauma center.

### Patterns of Drug Use

Many hospitalized trauma patients have used several drugs at the same time. Studies have shown that one-third or more of patients with traumatic injuries who test positive for alcohol have at least one other drug in their systems (Clark and Harchelroad, 1991). The presence of alcohol, therefore, should be a red flag for the presence of other drugs. In persons who test negative for alcohol, combinations of other drugs are frequently found (Brookoff et al., 1993; Soderstrom et al., 1992).

The issue of polydrug use provides further reason for AOD screening of trauma patients. As discussed in the previous chapter, several organ systems can be involved in a single traumatic injury. That fact, coupled with the high incidence of polydrug use, compounds the complexity of treating the trauma patient. The information gained from AOD screening can be an important aid in assessing injury and how it should be treated.

## When to Screen

In trauma centers, where procedures are prescribed by strict protocols, and blood and urine samples are drawn routinely from all patients, it is relatively simple to fit BAC and urine drug screens into existing procedures. This use of screens may be more difficult in a community emergency department, where patients with altered mental status may be the only ones likely to be screened, and the decision to screen is left to the individual physician.

The total amount of time spent in the emergency department by a patient can be as short as several minutes. Many patients are critically injured, and any treatment delay could mean permanent disability or death; therefore trauma treatment procedures in the emergency department must be as brief as possible. If chemical screening is to be done for AODs, it must be part of the standard treatment protocol, because of the short period that the trauma patient may be in the emergency department.

If chemical screening is to be done for AODs, it must be part of the standard treatment protocol, because of the short period that the trauma patient may be in the emergency department.

The laboratory process of carrying out BACs and urine drug screens can usually be completed in less than an hour, although hospital procedures can delay the reporting of test results for as long as 24 hours. Timely reporting of results is a key factor in an effective screening program. As discussed in Chapter 3, elevated blood alcohol levels or evidence of other drugs of abuse indicate patients who may develop withdrawal syndromes and those who may require adjustments of pain medications and anesthetics. Trauma nurses are often very familiar with a patient's blood alcohol level and use that information to make decisions about timing of discretionary medications such as morphine or meperidine (Demerol). When a patient comes back from the operating room, this information affects management since nurses are adjusting the dosage of various drugs minute to minute.

A large number of patients admitted to the hospital will be short-stay patients, discharged the day after they are admitted. So that these patients are not overlooked, it is important that the results of their BACs and urine drug screens be available at least by early in the morning on the day after their admission so that some intervention, however brief, can be attempted if deemed necessary. It is often helpful to designate a staff person to be responsible for monitoring BACs and urine toxicologies of newly admitted patients. This monitor could be, for example, the trauma physician, a trauma nurse, a social worker, the trauma nurse coordinator, or an AOD counselor.

### The Case for Universal Screening

As stated at the beginning of this chapter, the TIP consensus panel agreed that all hospitalized trauma patients aged 14 and over should be screened for AOD use and that screening of younger patients should be done if use were suspected. Screening should be performed for purposes of medical and nursing management and for gathering information regarding the need for future AOD intervention. Deciding to screen some patients and not others opens the door for cultural, racial, gender, and age biases.

A simple story illustrates this point. A mother, age 40, and her 18-year-old son were admitted to a hospital trauma center in a midwestern city after an automobile crash. The son, because of his age, was screened for blood alcohol. That test result was negative. The mother, a well-dressed woman, was not screened. Three days later she began showing signs of alcohol withdrawal.

Studies show that it is impossible to tell from a visual examination which patients are intoxicated (Perper et al., 1986; Rutherford, 1977). Sometimes patients are not responsive and do not give the expected behavior cues, and it is difficult even for people experienced in the trauma setting to make accurate judgments. Even a physical examination by a neurologist can fail to identify intoxication. The well-dressed, middle-class, 40-year-old woman was not identified as an alcohol user because of her physical appearance and possibly because of gender stereotypes. Intoxication can be overestimated as well as underestimated. For example, a patient judged to be intoxicated may be exhibiting the effects of oxygen deprivation.

If screening is universal and a part of the trauma center or hospital routine, problems caused by discretionary screening will be avoided. If screening is part of the standard treatment protocol, the patient is implying consent to screening by coming for treatment.

Deciding to screen some patients and not others opens the door for cultural, racial, gender, and age biases.

## Description of Laboratory Screening Tests

Several laboratory tests are available for determining the presence of alcohol and other drugs in body fluids such as urine and blood. The level of the substance in the body, especially the level of alcohol, indicates the degree of impairment at the time of the injury. Laboratory tests measure recent substance use rather than chronic use or dependence. There is no conclusive test to determine substance dependence that is similar to the blood sugar measurement to diagnose diabetes or the blood pressure measurement to identify hypertension.

Researchers and clinicians have developed a variety of brief screening tools, such as self-administered questionnaires and short sets of questions that focus on the quantity and frequency of substance use. The results of these nonlaboratory screening tools can help clinicians determine whether a patient is likely to be dependent on AODs and should be referred for a more comprehensive assessment. Because research has focused more on the use of alcohol than on the use of other drugs, many of these tools screen for alcohol dependence. However, some tools, such as the CAGE questionnaire, provided later in this chapter, can be adapted to screen for dependence on drugs other than alcohol.

The following sections describe laboratory and nonlaboratory screening tests for alcohol and other drugs.

### Blood Alcohol Concentration Determinations

There are a variety of methods for determining alcohol concentrations in the body. In the busy environment of the trauma center or emergency department, the simplest means is to use blood, since drawing blood is already a part of protocols at trauma centers and some hospitals. Other options exist, such as conducting a saliva test or using the Breathalyzer. However, the panel recommends the use of BACs.

Blood alcohol concentrations are measured in milligrams (mg) of alcohol per deciliter (dl) of blood. This figure is converted to a percentage. One hundred mg/dl equals 100 mg percent or 0.1 percent. Thus, a BAC of .1 mg percent is equivalent to a concentration in blood of 100 mg of alcohol per deciliter of blood.

While the level of BACs will vary greatly, most patients admitted to trauma centers have BACs well over the legal limit that defines drunk driving in most States (that is, 100 mg/dl) and well over the amount known to produce impairment (see below). For the 5-year period from July 1988 through December 1993, the average BAC for patients admitted to the University of Maryland's Shock Trauma Center among both men and women 21 to 34 years of age was 180 mg/dl (Soderstrom et al., 1994b). Further analysis of data from all 18,000 patients tested during that period indicated that the mean BAC was 180 mg/dl. Similarly, among nearly 2,300 trauma patients tested at the trauma center at Seattle's Harborview Medical Center over an 18-month period, the mean BAC for those testing positive was 180 mg/dl (Jurkovich et al., 1992). Both of these studies involved Level 1 trauma centers, where the most severely injured patients are transported. These patients are likely to have higher levels of impairment from alcohol. However, such elevated BACs are seen commonly in trauma patients in community hospitals.

The amount of alcohol that defines drunk driving in most States is 100 mg/dl (or .1 percent), which is well above the amount known to produce impairment (about 50 mg/dl).

A level of 100 mg/dl is usually achieved when a person weighing 70 kilograms drinks three to four drinks per hour. A standard drink is defined as 12 ounces of beer, 1 ounce of liquor or distilled spirits, or 4 ounces of wine. However, there is some variability because of individual differences in alcohol metabolism, which varies because of such factors as stomach contents (food ingested), speed of alcohol consumption, gender, age, and body size.

Impairment from alcohol consumption has been shown to occur at the level of 50 mg/dl. In women and elderly persons, impairment may occur at lower levels. Most people demonstrate impaired driving at levels of 50 to 70. The probability that an auto crash will occur begins to rise when the driver's BAC exceeds 40 mg/dl, and rises dramatically when it reaches 100 mg/dl (American Medical Association, Council on Scientific Affairs, 1986). A level of 150 or higher without noticeable intoxication indicates a high degree of tolerance to alcohol.

Many patients with blood alcohol concentrations higher than 200 mg/dl will be found to have a diagnosable alcohol problem upon further screening and assessment. Such patients are likely to have chronic medical problems because of alcohol use— problems that will complicate the course of treatment for their injuries (Gentilello et al., 1993). Levels above 400 mg/dl can be lethal, although this level for lethality varies from person to person.

Alcohol use by trauma patients may be underestimated because BACs are determined after the patient has been transported from the site of the injury. Most persons metabolize alcohol at a rate of 15 to 20 mg per hour. Thus, the longer the time between injury and testing, the lower the BAC. Many patients must be extricated from their vehicles, and many are transported relatively long distances, allowing for metabolism of a significant amount of alcohol. Frequently at the scene of the injury and during transport, patients are given intravenous fluids that dilute the blood and lower BAC results. Vomiting may eliminate alcohol from the stomach before it reaches the blood.

Many patients with blood alcohol concentrations higher than 200 mg/dl will be found to have a diagnosable alcohol problem upon further screening and assessment.

A single elevated blood alcohol level does not provide information about the regularity and severity of alcohol abuse, unless the counts are extremely high. From the screening perspective, the BAC is just one factor that must be taken into consideration when determining the severity of the problem and making an appropriate referral for care.

### Urine Drug Screening

As discussed above, trauma patients at Level 1 trauma centers routinely have urine specimens sent for analysis for purposes other than AOD screening. Therefore, in this setting, urine screening for the presence of drugs can be done with a minimal disruption of trauma center activity. At community hospitals where urine specimens may not be routinely analyzed, emergency department physicians must order them. Not all hospitals have the facilities to perform urine drug screens, but outside laboratories can be used.

In the laboratory, a number of different tests are performed to detect the presence of various drugs. Different test procedures have the capability of detecting different drugs. Testing capabilities differ in hospital laboratories, because of the available instrumentation and the training of laboratory personnel.

There is no single set of test procedures that constitutes a standard urine drug screen. The range of the screening test will vary from locale to locale and should be defined within each institution according to its needs and capabilities. Institutions should design screening tests to detect drugs that they believe are important and feasible to look for and prevalent in their geographic areas.

In screening of the general population, particularly workplace screening, marijuana is one of the more commonly found drugs, especially in young people. Use of drugs such as PCP and hallucinogens is generally less common than use of marijuana. The 1993 survey of drug use among high school seniors showed a significant increase in the use of the hallucinogen LSD (Johnson et al., 1994). Standard toxicologic tests do not screen for hallucinogens or inhalants. LSD is detectable in urine by the EMIT test up to 1 day after use (American Bar Association Center on Children and the Law, 1991).

If the urine screening test comes back negative for drugs, this result means that within the detection limitations of the drugs that were looked for, no drugs were found. No single toxicology test can determine that a patient has ingested no drugs at all.

A positive screen for any nonprescribed psychoactive substance should be a strong factor in the attending physician's decision to order an AOD assessment, if the patient consents. It is important to note, however, that positive results are not 100 percent definitive. If a confirmed positive result is required, a second test of a different type must be performed. Positive results of initial toxicologic screens are not confirmed by a laboratory unless a second test is specifically requested. This test is frequently done at an offsite laboratory and is relatively expensive to perform; results may not be returned for days. Therefore, such confirmatory tests are generally of no clinical value. A practitioner receiving unconfirmed positive test results may want to consult with the hospital laboratory about the meaning of the results and what the consequences of acting on these results might be.

There is no single set of test procedures that constitutes a standard urine drug screen. The range of the screening test will vary from locale to locale.

Positive results of urine drug screens may not indicate use or impairment at the time of injury, because metabolites of some drugs remain detectable for days or weeks after use. Cocaine, crack, and amphetamines may be detected in the urine more than 72 hours after use. Commonly used tests for marijuana measure a metabolite that is detectable in urine or blood for weeks after use. However, at least one study has used a more sophisticated test (radioimmunoassay) to determine marijuana use proximate to trauma. That work, a study of 1,023 victims of vehicular and nonvehicular crashes admitted to the University of Maryland's Shock Trauma Center, found that more than one-third (34.7 percent) had used marijuana within 4 hours of the time of injury. (Almost half of those patients also had positive blood alcohol concentrations.) New tests for marijuana are being developed, and there is a possibility that a test will become available on a widespread basis to determine recent use.

Positive results of urine drug screens may not indicate use or impairment at the time of injury because metabolites of some drugs remain detectable for days or weeks after use.

Finally, negative results of laboratory tests for alcohol and other drugs do not definitively indicate that the patient does not have an AOD problem. For example, Rivara and associates (1993a) found that 25 percent of trauma patients who had negative BAC results tested positive for possible alcoholism on the short version of the Michigan Alcohol Screening Test (SMAST), a brief questionnaire described later in this chapter. Similarly, Soderstrom and colleagues (1992) noted that 15 of 24 trauma center patients (63 percent) who tested negative for alcohol at the time of admission had a current or past substance use disorder.

In short, although chemical testing is an invaluable part of AOD screening, one needs to understand the limitations of tests and evaluate results on an individual basis.

### Other Chemical Testing

Some laboratory screening tests can be used to determine whether a patient is a chronic user of alcohol. These tests measure injury to liver cells and to the cells that manufacture red blood cells. A liver function test that indicates an elevated level of gamma-glutamyltransferase (GGT) and a complete blood count that indicates that the red blood cells have a greater than normal mean corpuscular volume (MCV) are both evidence of chronic alcohol abuse.

## Description of Screening Questionnaires and Interviews

Screening for behavioral and medical signs of AOD problems is generally performed using a questionnaire that is administered by a member of the trauma team at the time of admission or when the patient is stable. Self-administered questionnaires are also available. In deciding which of the several available questionnaires to use, consideration should be given to whether a trained screener is needed, whether the test can be self-administered, and how much time is required and will be available for administering the questionnaire. No single screening instrument can be used with all injured patients.

Studies to determine whether a certain method of administering screening tests is superior (for example, face-to-face interviews, paper-and-pencil test, or computerized test) showed that various methods yielded similar results (National Institute on Alcohol Abuse and Alcoholism, 1993).

During administration of the screening questionnaire or brief interview, the interviewer should take the opportunity to ask about other factors relating to the patient's behavior and lifestyle. These factors include smoking, diet, and exercise, which may have a bearing on the addiction problem itself or on other health conditions. Asking screening questions about substance abuse within this context reduces the patient's apprehension and increases his or her sense that the healthcare team is concerned about the whole person.

The consensus panel that developed this TIP felt that hospitals and trauma centers developing a screening program would wish to review many available instruments. Thus, several have been described and reproduced in the following section. Facilities may use an existing instrument or develop a screening tool based on questions from several instruments. Only the Michigan Alcohol Screening Test (MAST) has been extensively validated for use with trauma patients.

In deciding which of the several available questionnaires to use, consideration should be given to

- Whether a trained screener is needed
- Whether the test can be self-administered
- How much time is required and will be available for administering the questionnaire.

### Alcohol Screening Questions

Alcohol screening questions generally focus on the quantity and frequency of alcohol use. Several questions have been recommended, although not enough research has been done on which are the most effective. Examples of questions include

- "How many days per week do you drink?" (frequency)
- "On a day when you drink alcohol, how many drinks do you have?" (quantity)
- "How many times in the last month did you drink more than five drinks at one sitting?" (binge drinking).

Research by Anda and associates (1988) has indicated a high correlation between binge drinking and injury. As discussed below, the context in which the questions are asked and the skills of the screener in asking them are important factors.

Cyr and Wartman (1988) found that asking just two questions in combination enabled them to detect alcoholism in more than 90 percent of a group of 47 alcoholic patients. The questions were, "Have you ever had a drinking problem?" and "When was your last drink?"

To minimize problems of inaccurate self-reporting, it is important to ask about specific amounts of drinking, rather than average amounts; to define a single drink; to inquire about specific amounts of beer, wine, and hard liquor; and to inquire about the frequency, quantity, and occasions of heavier use with separate questions (Cutler et al., 1988; Sobell and Sobell, 1990).

Asking just two questions in combination has been shown to detect alcoholism in more than 90 percent of a sample. The questions are

- "Have you ever had a drinking problem?"
- "When was your last drink?"

### Alcohol Screening Tests

#### MAST and SMAST

The Michigan Alcohol Screening Test, developed in 1971 as a structured interview instrument with 25 questions, is one of the oldest and most commonly used screens to detect alcoholism. Among hospitalized trauma patients, it is the most frequently used instrument and the most extensively validated. The SMAST, presented in Exhibit 4-1, has also been used with similar reliability (Selzer et al., 1975). Evaluation data indicate that it is an effective diagnostic instrument and does not have a tendency to produce false positives, as does the MAST. Positive answers to four or more questions indicate the presence of an alcohol problem.

#### CAGE

The CAGE is another widely used questionnaire (Ewing, 1984; Mayfield et al., 1974). It has not been verified in trauma populations, although its sensitivity and specificity have been widely investigated and validated in a variety of populations. Among screening instruments for alcoholism, it is perhaps the shortest, consisting of four questions (see Exhibit 4-2). Two or more affirmative responses indicate with high likelihood that the patient is a problem drinker. Use of the CAGE with elderly populations has suggested that a positive response to one of the four questions is a better cutoff score (Buschbaum et al., 1991).

Exhibit 4-2 CAGE Questionnaire

CAGE Questionnaire

1. Have you felt the need to C ut down on your drinking?
2. Do you feel A nnoyed by people complaining about your drinking?
3. Do you ever feel G uilty about your drinking?
4. Do you ever drink an E ye-opener in the morning to relieve the shakes?

Source: Ewing, 1984; Mayfield et al., 1974.

The CAGE is very brief, and therefore costs to administer are low. Sensitivity of the CAGE is relatively high; it is able to detect alcoholism in 85 percent of alcoholic patients. The specificity of the CAGE is over 90 percent, meaning that it is able to distinguish alcoholics from nonalcoholics in 90 of 100 cases.

A common criticism of the CAGE is that it is not gender sensitive—that is, women who are problem drinkers are less likely than male problem drinkers to screen positive when this instrument is used. One study of more than 1,000 women found that asking simple questions about frequency and quantity of drinking, coupled with a question about binge drinking, was better than the CAGE in detecting alcohol problems among women (Waterson and Murray-Lyon, 1988).

Others have raised the issue that the CAGE identifies only persons who are alcohol dependent. Screening programs that rely only on the CAGE as a screen for alcoholism may not identify persons whose frequency and quantity of drinking (binge drinking) put them at risk of alcoholism.

Finally, the CAGE asks about "lifetime" experiences rather than current drinking problems. A person who no longer drinks may screen positive on the CAGE.

Screening programs that rely only on the CAGE as a screen for alcoholism may not identify persons whose frequency and quantity of drinking (binge drinking) put them at risk for alcoholism.

#### AUDIT

Another relatively short screening test for alcohol dependence was developed by the World Health Organization (Babor and Grant, 1989). The Alcohol Use Disorder Identification Test (AUDIT) consists of questions that have reliably identified high-risk drinkers in a six-nation study. Based on answers to a 150-item assessment, ten key questions were selected that were highly correlated with hazardous or harmful alcohol consumption. These ten questions are presented in Exhibit 4-3. They include three questions about alcohol use, four about dependence, and three about problems resulting from drinking. The 10-item AUDIT can be given as a self-administered test, or the questions can be read aloud. The AUDIT takes about 2 minutes to administer.

The responses to the ten questions are each scored from 0 to 4, with a maximum score of 40. Among patients diagnosed as exhibiting hazardous or harmful use of alcohol, 92 percent had an AUDIT score of 8 or more. Using a cutoff score of 8, the AUDIT has a sensitivity of 92 percent and a specificity of 87 percent (Saunders et al., 1993).

Compared with the SMAST, the AUDIT has been found to be better at detecting current alcohol problems. Barry and Fleming (1990) used the AUDIT or CAGE in a sample of 2,500 patients and found that when the first three questions of the AUDIT were modified, it identified 40 percent more patients at risk of problem drinking than the CAGE.

The modified AUDIT questions were

- "How many days per week do you drink?"
- "On a day when you drink alcohol, how many drinks do you have?"
- "How many times in the last month did you drink more than five drinks at one sitting?"

Particular strengths of the AUDIT in regard to screening of trauma patients are that it is designed for use in a primary healthcare setting, it provides early detection of hazardous and harmful drinking, and it is focused on present use rather than lifetime use.

#### SAAST

The Self-Administered Alcohol Screening Test (SAAST) was adapted from the MAST and focuses on detection of dependence (Swenson and Morse, 1975). It differs from the MAST by including an additional nine items on symptoms and some checks on consistency of responses. It uses a simple unweighted method of scoring. It has been reported to have a sensitivity of 95 percent. However, it is somewhat lengthy (35 items) for use as a screening instrument.

#### ADS

The 25-item Alcohol Dependence Scale (ADS) is a self-administered questionnaire that was designed to measure elements of the alcohol dependence syndrome, which was first postulated by Edwards and Gross (1976) and has since become the core concept of the Diagnostic and Statistical Manual of Mental Disorders (DSM-IV) diagnostic criteria (American Psychiatric Association, 1994). The DSM-IV criteria are commonly used as a basis for diagnosing dependence and substance use disorder.

The ADS focuses on drinking behavior in the previous 12 months. It measures impaired control over alcohol use, salience of alcohol-seeking behavior, tolerance, withdrawal symptoms, and a compulsive drinking style. The ADS and the MAST have been found to complement each other in that the MAST assesses the degree of problems related to alcohol use and the ADS yields a quantitative index of the severity of alcohol dependence (Ross et al., 1990).

When used as a screening tool in a sample of more than 500 AOD abuse treatment patients, the ADS was found to be as sensitive as the MAST in detecting alcohol disorders (Ross et al., 1990). In choosing between the two, clinicians could be guided by their screening objectives—whether to look for level of dependence or for consequences of dependence.

#### HSS

The Health Screening Survey (HSS) is a 10-item masked alcoholism screening instrument (Wallace and Haines, 1985). It consists of the CAGE questions, questions about frequency and quantity of use, history of use and problems, and the Skinner Trauma Scale. Although it was found to have high sensitivity when used with samples of alcoholic patients, its sensitivity in a community primary care setting was low (Fleming and Barry, 1991). Because some of the 10 items have subparts, the HSS is longer than several other screening instruments in use.

#### T-ACE

The T-ACE, which was developed for use by obstetricians and gynecologists to detect high-risk drinking in women (Sokol et al., 1989), is a modification of the CAGE. The T-ACE has four questions. A question on tolerance (T) is substituted for the CAGE item concerning guilt. The item asks, "How many drinks does it take to make you high?" or "How many drinks can you hold?" The other three questions are the CAGE questions on feeling annoyed or guilty and on having an eye-opener (a drink first thing upon awakening). The developers of the instrument found that its sensitivity was high and that it was better than the MAST or CAGE in identifying risk-drinking behavior.

The T-ACE has been validated only with pregnant women. However, instruments developed for this specific population are based on research showing gender differences in drinking behaviors. Therefore, questions included in such instruments may be better at detecting alcohol problems in all women, not just pregnant women.

#### NET

The NET, also developed for use with pregnant women (Bottoms et al., 1989), has three questions. One question is from the MAST: "Do you consider yourself a normal drinker?"; one is from the CAGE: "Do you ever have an eye-opener?"; and one is from the T-ACE: "How many drinks can you hold?" A response indicating more than three drinks scores positive on the last item.

The developers found the NET to be comparable to the MAST, CAGE, and T-ACE in sensitivity. Its sensitivity has been validated only with pregnant women.

In a study of more than 7,000 women at a prenatal clinic, the TWEAK was found to be more sensitive than the CAGE or MAST and more specific than the T-ACE.

#### TWEAK

The TWEAK (Russell, et al., 1991) was also developed for use with pregnant women. It consists of five items that assess tolerance (T); worry (W): "Have close friends or relatives worried or complained about your drinking?"; eye-opener (E); amnesia (A): "Has a friend or family member ever told you things you said or did while drinking that you could not remember?"; and the need to cut down on drinking (K).

A 7-point scoring system is used; 2 points are given for positive responses to either of the first two questions (tolerance and worry), and positive responses to the other three questions score 1 point. A cutoff score of two indicates the likelihood of risk drinking.

In a study of more than 7,000 women at a prenatal clinic, the TWEAK was found to be more sensitive than the CAGE or MAST and more specific than the T-ACE.

### Screening Tests for Other Drug Abuse

#### CAGE-AID

The CAGE-AID (CAGE Adapted to Include Drugs) modifies the CAGE questions for use in screening for drugs other than alcohol (Exhibit 4-4). Brown and Rounds (1991) tested its usefulness with 124 patients in a community family practice. It was found to have a sensitivity of 79 percent and a specificity of 77 percent. The authors suggested that stigma associated with use of illicit drugs may have limited its sensitivity. Like the CAGE, the CAGE-AID focuses on lifetime use; although individuals who are dependent may screen positive, individuals who are at risk may not.

Exhibit 4-4 CAGE-AID

CAGE-AID

1. Have you felt you ought to cut down on your drinking or drug use?
2. Have people annoyed you by criticizing your drinking or drug use?
3. Have you ever felt bad or guilty about your drinking or drug use?
4. Have you ever had a drink or used drugs first thing in the morning to steady your nerves, get rid of a hangover, or get the day started?

Source: Brown and Rounds, 1991.

#### DAST

The 28-item Drug Assessment Screening Test (Skinner, 1982) was modeled on the MAST. It is a self-administered screen and contains detailed instructions for completing it. It focuses on the extent of problems related to drug use. It does not screen for frequency of drug use or the specific drug used.

A 20-item shortened version was found to have a sensitivity of 85 percent (Gavin et al., 1989). A ten-item version was also tested and found to be nearly as sensitive as the 28-item version (Skinner, 1993). It has not been tested in a primary care setting.

As with other screens for illicit drug use, respondents may answer negatively.

#### SSI

The Simple Screening Instrument (SSI) for AOD Abuse was developed by a consensus panel for the Center for Substance Abuse Treatment(see the TIP 11 in this series entitled Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases). Source instruments for the questions included the MAST, CAGE, DAST, Problem-Oriented Screening Instrument for Teenagers (POSIT), HSS, AUDIT, and the Skinner History of Trauma Scale. It has 16 items and was developed for use by community outreach workers to provide a comprehensive screen for alcohol and other drug abuse. Two versions of the SSI were developed, one for self-administration, and one for use by an interviewer. Although the developers recommend administering the entire instrument, four questions can be used as a short screen.

The SSI also has a clinical observation checklist for signs and symptoms of AOD abuse (for example, needle track marks, tremors, and dilated or constricted pupils). The SSI has not been validated.

Descriptions of the screening instruments described here are presented in Exhibit 4-5.

Exhibit 4-5 Summary of Screening Instruments

Summary of Screening Instruments
Name | Recommended Cutoff Score | Population | General Comments
Alcohol Dependence Scale (ADS) (Horn et al., 1984) | Optimum cutoff score is 9; 12 if patients must meet all DSM-IV criteria; 14-21 indicates intermediate level of dependence; 22-30 indicates substantial dependence. | Adults | Rather lengthy as brief screen--25 items, self-administered; yields quantitative index of severity of dependence; focuses on behavior in past 12 months; complements MAST; assists in making diagnosis based on DSM-IV criteria.
Alcohol Use Disorder Identification Test (AUDIT)(Babor and Grant, 1989) | Possible score ranges from 9-40; 8 points or more indicate need for assessment. | Adults | Ten items; developed with multinational samples and widely validated; provides information on use and problem history in past year; does not detect past alcohol use problems.
Drug Assessment Screening Test (DAST) (Skinner, 1982) | Positive responses to five or more questions indicate likelihood of drug abuse. | Adults | Twenty items; yields quantitative index of degree of problems related to drug use; well validated; excellent diagnostic accuracy with respect to DSM-IV criteria.
CAGE (Ewing, 1984; Mayfield et al., 1974) | Two or more positive responses indicate need for assessment; with elderly, one positive response is an indicator. | Adults | Short--four items; easy for treatment professionals to remember; assesses lifetime consumption; does not measure levels of consumption or episodes of heavy drinking; may miss at-risk drinkers and women with drinking problems; good sensitivity and specificity; validated in many populations.
CAGE Adapted to Include Drugs (CAGE-AID) (Brown and Rounds, 1991) | Two or more positive responses indicate need for assessment. | Adults | Short--four items; advantages and disadvantages are same as for CAGE.
Health Screening Survey (HSS) (Wallace and Haines, 1985) | Depends on goals of screening program. | Adults | Rather lengthy as a brief screen--10 items on alcohol, with subparts; contains parallel questions on smoking, exercise, and weight to mask alcohol screening; well validated in primary care settings, although low sensitivity (78 percent); may be less sensitive in detecting alcohol problems in women.
Michigan Alcoholism Screening Test (MAST) (Selzer, 1971) | Optimum cutoff score is 13; 18 if patients must meet DSM-IV criteria. | Adults | Rather lengthy as a brief screen--25 items; assesses degree of lifetime alcohol-related problems; does not contain quantity-frequency questions; complements ADS; strong documentation of validity--used as "gold standard"; most accurate with heavy drinkers who recognize they have a problem; less accurate with at-risk drinkers.
NET (Bottoms et al., 1989) | Positive response to three questions. | Female adults | Brief--three questions; developed for use with pregnant women; sensitivity and specificity comparable to MAST, SMAST, CAGE, T-ACE; not validated with other groups.
Problem-Oriented Screening Instrument for Teenagers (POSIT) (National Institute on Drug Abuse, 1990) | One or more positive responses. | Adolescents | 14-item subscale measuring alcohol and other drug use and abuse; part of Adolescent Assessment Referral System; validity studies not completed.
Self-Administered Alcoholism Screening Test (SAAST) (Swenson and Morse, 1975) | Ten points or more; items are unweighted. | Adults | Rather lengthy as a brief scan--35 items; focuses on detection of dependence.
Short MAST (SMAST) (Selzer et al., 1975) | Two points or more; items are weighted. | Adults | Brief--13 items; well validated in primary care settings.
T-ACE (Sokol et al., 1989) | Positive response to four questions. | Female adults | Brief--four questions; developed for use with pregnant women; reliably differentiates at-risk drinkers from nonrisk drinkers; not validated with other groups.
TWEAK (Russell et al., 1991) | Possible score of 7; items are weighted; 2 points or more indicate likelihood of risk drinking. | Female adults | Brief--five items; developed for use with pregnant women; offers advantages over the CAGE or MAST for detecting problem drinking in women.

## Evaluating Results of AOD Screening

All the guidelines discussed here should be considered within the context of individual clinical judgment.

Blood alcohol concentrations greater than 20 mg/dl, an abnormally elevated GGT, more than two positive answers on the MAST or any other positive test on a screening questionnaire, or any positive drug screen for a psychoactive substance in urine screening indicate that the treating physician should determine whether the patient should be referred for further AOD assessment.

- Blood alcohol concentrations greater than 20 mg/dl
- Any positive urine drug screen for a psychoactive substance
- An abnormally elevated GGT
- More than two positive answers on the MAST or any other positive test on a screening questionnaire.

### AOD Screening of Special Populations

Certain special populations of hospitalized trauma patients require special considerations in screening. These include patients who are

- Homeless
- Brain injured
- Illiterate
- Non-English speaking
- Adolescents
- Pregnant
- Elderly
- Victims of domestic violence
- Mentally ill
- Hearing-impaired or deaf.

It is unlikely that special needs will be an issue in chemical screening, which depends simply on drawing blood and urine. With questionnaires, such groups as the brain injured, the non-English speaking, adolescents, and patients with mental illness may require screening by personnel who are sensitive to their special needs and trained to address them. Elderly persons may be especially reluctant to discuss substance use problems because of the stigma they associate with such problems.

## AOD Assessment

Assessment is a comprehensive process that goes beyond medical issues to include a broad range of biopsychosocial components. It should be done by a clinician with specialized training in assessing and treating substance use disorders. Throughout the following discussion, this person is referred to as an AOD clinician or AOD specialist. Persons who can fulfill this role are described below.

Assessment is a comprehensive process that goes beyond medical issues to include a broad range of biopsychosocial components.

### When to Assess

If positive results of screening are received, the attending physician should consider ordering an AOD assessment, if the patient consents. The timing of the assessment must be tailored to the patient's capability to communicate and participate and the patient's receptivity to the process. Other factors to consider when deciding when to assess include the projected length of hospital stay, ongoing medical procedures, and whether the hospital has an inpatient treatment program. Another factor to consider is "the teachable moment," which was discussed in Chapter 3. AOD assessment as soon as possible after the injury may help the patient to make the connection between AOD use and the injury. A general rule is to conduct an assessment as soon as possible after the need for it has been identified.

An argument for delaying the assessment comes from a study that found that patients were less likely to follow through with recommendations from assessment if it were done early during their hospital stay, when they were primarily concerned with their medical needs (Gentilello et al., 1988). Intervention provided as closely as possible to the time the patient could begin treatment was the most effective.

Early assessment is important for medical reasons to evaluate for the possibility of withdrawal. Another reason to assess as soon as possible is the need to improve pain management for patients who require additional medication. Some institutions have physicians on staff who are addiction specialists; consultation with these physicians may be necessary for patients in whom AOD withdrawal is suspected or anticipated or who require specialized pain management.

### Patient Consent

When the treating physician is considering ordering an AOD assessment, he or she should communicate to the patient his or her concern about the possible contribution of alcohol and other drug use as a contributing factor. The physician should encourage the patient to agree to the assessment and participate fully in it. Another approach is to explain to the patient that the policy of the hospital is that patients who have positive laboratory screening tests should discuss their alcohol or other drug use with an AOD specialist.

The manner in which the idea of assessment is introduced to the patient is an important factor in gaining patient consent and participation. In hospitals where AOD screening programs are in place and staff have been trained to recognize and respond to substance abuse, patients may begin to feel early in their stay that discussing their substance abuse problems is possible. In some cases, the attending physician may not feel that he or she has the time or skill to adequately address positive screening results. However, the importance of the relationship between physician and trauma patient should not be underestimated. Expressions of concern about the patient's AOD use, coupled with a nonjudgmental attitude, will generally go a long way toward engaging the patient in the assessment process.

In hospitals where AOD screening programs are in place and staff have been trained to recognize and respond to substance abuse, patients may begin to feel early in their stay that discussing their substance abuse problems is possible.

### Where to Assess the Trauma Patient

The assessment must be done confidentially, and the location should be chosen with this in mind. A patient's room is the most likely setting, but using this area may present some problems, particularly if it is not a private room. It may be up to the assessor to put the patient in a wheelchair and take him or her to a private location, such as a vacant office or conference room. The patient may choose to be accompanied by a family member or friend.

### Who Performs the AOD Assessment

AOD assessment requires a high level of knowledge and skill. The assessment should be performed by an AOD clinician who possesses good interviewing techniques and who is sensitive to cultural-ethnic and gender issues. Such personnel can include

- Physicians with specialized training
- Nurses with specialized training
- Social workers with addiction training
- AOD counselors
- Physician's assistants with specialized training.

Properly trained AOD clinicians maximize opportunities to motivate patients.

The assessor should have certified training in evaluating and treating persons with substance use disorders. A nonjudgmental, empathic attitude is crucial to the success of this process.

### The Assessment Process

Assessment can be approached in a variety of ways by a variety of personnel. Face-to-face AOD assessment is a challenging and often difficult task, in particular because of the denial that nearly always surrounds substance use problems. The assessor should have certified training in evaluating and treating persons with substance use disorders. A nonjudgmental, empathic attitude is crucial to the success of this process. The interviewer must know how to confront traits not seen as frequently in non-substance-abusing populations. These include shame, manipulation, lying, minimization, belligerence, and anger.

The assessor should have a brief initial contact with the patient, introducing him- or herself and explaining why he or she is there. If the patient will be in the hospital for only a day, this first brief encounter may be all that is possible. Such an encounter may be limited to a brief educational intervention or advice about AOD use (see the discussion below of brief interventions). A skilled assessor usually can quickly establish a good rapport with the patient.

Patients may fear participating in the AOD assessment process if they do not understand the purpose of the process or the consequences of their responses. They may fear that the results of the AOD assessment will be obtained by the criminal justice system or that insurance companies will refuse to pay for treatment of injuries resulting from AOD use. Patients may also fear other consequences such as losing their jobs or the custody of their children. AOD assessment may be less threatening to the patient if the assessor assures the patient that the results will be kept in the strictest confidence. Specific measures for maintaining confidentiality can be mentioned, for example, use of consent forms (see Chapter 6). The assessor can state that the goal of the assessment is not to force the patient to accept unwanted or unnecessary treatment but to help the patient make choices that could prevent reinjury.

As discussed above, the initial result of a urine drug screen may be false, and it may be the hospital's policy not to confirm these results because of costs. Therefore, the interviewer must be diplomatic when raising the topic of drug use with the patient. The assessor may want to consult with the laboratory first.

Facilities should examine their own resources and make decisions about how they can best be used. They may also consider looking outside their own walls. A trauma center or hospital treating injured patients may want to establish a linkage with an AOD treatment center to ensure comprehensive AOD assessment. Since it is usually the role of the patient's primary physician to initiate the process of comprehensive AOD assessment, it is important that the physician be knowledgeable about the implications of positive screening results. It is also important that the physician know the hospital and community resources for AOD assessment and treatment so that he or she can make referrals directly.

Since it is usually the role of the patient's primary physician to initiate the process of comprehensive AOD assessment, it is important that the physician be knowledgeable about the implications of positive screening results.

### Special Concerns in AOD Assessment Of Trauma Patients

Traumatic injuries can complicate the AOD assessment process in both physical and psychological ways. On the most basic physical level, the patient may be unable to cooperate with the assessor. Intubation, which involves inserting a tube into the patient's trachea, restricts the patient's ability to communicate verbally. Medications may also impair the patient's mental status. Patients may be heavily sedated or lethargic. Traumatic brain injury may result in significant cognitive impairment.

Psychologically, patients will probably be focused on the current crisis—the traumatic injury -- and may be unwilling to shift their focus to talk about the AOD problem. They may also be experiencing sensory overload from the environment of the trauma center or hospital; for example, many people may be going in and out of the room, and the medical equipment in the room may be intimidating or frightening. The support and concern of family, friends, physician, and hospital staff are important elements in gaining the patient's participation.

Trauma patients fall into a wide age range, and age can be a factor influencing the AOD assessment process at both ends of the spectrum. Adolescents, for example, are likely to be unwilling to participate in assessment and resistant to the message that some kind of intervention is necessary. The elderly may be difficult to communicate with because of hearing, cognitive, or other problems. Many elderly people view alcoholism or other drug abuse as shameful and may not be aware that addiction is a treatable disease. Some elderly people may rationalize their AOD abuse by stating that "life is not worth living" without alcohol or another drug. Many elderly persons fear losing their independence and do not realize that continued use threatens the independence that they value so much.

Culturally sensitive assessors are an essential part of a successful assessment process. The skilled assessor will be able to take different approaches with individual patients, as needed. Attention must be given to the special issues involved with special populations, as listed above in the discussion of screening. Factors that should be considered include socioeconomic group, ethnicity, gender, and type of injury.

Patients' families should be brought into the assessment process whenever possible, if the patient consents. Their role is particularly important if the patient's ability to participate is limited. Families may deny or minimize the patient's AOD use. On the other hand, families of patients with AOD problems are often eager to talk about these problems with someone. However, as discussed in the next chapter, efforts must be made to protect the patient's privacy and confidentiality.

Patients' families should be brought into the assessment process whenever possible, if the patient consents.

All of these factors highlight the importance of having a skilled AOD assessor who is flexible enough to adapt to the special circumstances that are involved for the trauma patient.

### Assessment Instruments

Specific tools have been formulated to assist in AOD assessments of adolescents and adults. Several assessment instruments for use with adolescents have been reproduced in the TIP Screening and Assessment of Alcohol- and Drug-Abusing Adolescents. The Assessment Severity Index (ASI), which is perhaps the most widely used AOD assessment instrument in adult populations, is reproduced in the TIP 7: Screening and Assessment for Alcohol and Other Drug Abuse Among Adults in the Criminal Justice System. A comprehensive discussion of assessment tools was considered by the panel to be beyond the scope of this TIP, the main focus of which is screening. However, the panel agreed on certain components that should be included in a comprehensive AOD assessment.

### Components of the Assessment

The AOD assessment consists of a number of distinct components, and there is a formulation that occurs in piecing together the components to lead to a set of comprehensive, cohesive observations and recommendations. The assessment also takes into account laboratory screening results (such as BAC and urine toxicology tests).

The components of a complete assessment include a medical and psychiatric history, a physical examination, a mental status examination, a history of AOD use, and patterns of use. Assessment of several other life areas, such as family and employment status is also important, but is not described in detail here.

Medical history. The medical history should be focused on the patient's use of alcohol and other drugs. It should include the family medical history, including AOD problems of parents, siblings, aunts, and uncles. The patient's trauma history should also be included. The Skinner Trauma History, presented in Exhibit 4-6, consists of five questions about previous trauma injuries and is a simple way to gather this data. A score of two or more positive responses to the five questions has been shown to indicate a high probability of excessive drinking or alcohol abuse (Skinner et al., 1984). Obtaining the patient's trauma history is important because previous injuries are a primary predictor of future injury. Yet they are often not included in a typical medical history because many people do not view trauma as a disease.

Exhibit 4-6 Skinner Trauma History

Skinner Trauma History
Since your 18th birthday, have you; 1. Had any fractures or dislocations to your bones or joints?; 2. Been injured in a road traffic accident?; 3. Injured your head?; 4. Been injured in an assault or fight (excluding injuries during sports)?; 5. Been injured after drinking?

Psychiatric history. The psychiatric history should include the history of AOD use and treatment. AOD use and abuse problems are prevalent in people with psychiatric illnesses, although many psychiatric symptoms abate rapidly with abstinence. Some people use and abuse AODs in an attempt to self-medicate their psychiatric problems. In fact, in some cases, patterns of AOD abuse can improve psychiatric symptoms, but they may also worsen them. Especially in brain-injured patients, symptoms of AOD use can be misdiagnosed as psychiatric disorders.

Another TIP in this series, Screening, Assessment, and Treatment Planning for Patients with Coexisting Mental Illness and AOD Abuse, discusses assessment of this patient population.

Physical examination. The physical exam, to be performed by a physician, is focused on factors associated with AOD use. The physician should look for symptoms of withdrawal and signs of chronic use. Signs of chronic use include a perforated septum (cocaine sniffing), liver damage (alcohol), or track marks (injection drug use). Some elderly persons have long histories of substance use. It is especially important to attend to physical findings in this population, because many elderly persons will deny or minimize use.

Mental status examination. A mental status examination is a key element in AOD assessment and is needed to validate the accuracy of the assessment. This examination considers the patient's mental status in areas such as mood, memory, orientation, and affect. The level of cognition is another area to be evaluated, particularly in patients with traumatic brain injury. Level of cognition is an important factor in the consideration of patients' ability to participate in their treatment. Results of the mental status examination can also contribute to making a diagnosis of withdrawal symptoms.

AOD history of use patterns. Patterns of alcohol and drug use in the patient's past contribute important information that helps lead to a diagnosis of chronic use. Information about these patterns can be obtained from the patient, from family members and significant others, and from physical signs and symptoms.

A single factor that is highly predictive of traumatic injury is quantity/frequency of alcohol and drug use, specifically, binge use of substances. Binge drinking is generally defined as consuming between five and nine drinks at one sitting at least once a week. Excessive use on isolated occasions results in acute neurological impairment, which increases the risk of traumatic injury. An example of a binge drinker is the young drinker who drinks only on weekends, but consumes excessive quantities.

Other areas to assess. Other areas to assess include

- Social history
- Family history
- Environmental components
- Employment history
- Educational history
- Legal status, including involvement with criminal justice system
- Financial status.

### Determining an AOD Diagnosis

#### Negative Findings of Assessment

Some patients who screen positive for AOD use may not have a diagnosable AOD disorder. Some persons who are unaccustomed to drinking may show poor judgment in using alcohol and then driving. Such a person, who is likely to feel very guilty about drinking and driving and its consequences, may benefit from a reassuring comment from a healthcare professional about the dangers of driving after drinking and the need to avoid such behavior in the future, and probably nothing more as far as an AOD intervention is concerned.

#### Positive Findings of Assessment

A positive assessment results in a diagnosable condition of a substance abuse disorder, as defined in the Diagnostic and Statistical Manual of Mental Disorders (DSM-IV) (1994). Exhibit 4-7 presents DSM-IV criteria for substance dependence. The diagnosis will determine the severity of the substance use disorder and has to be considered in the context of traumatic injury as well as the biopsychosocial context.

Exhibit 4-7 DSM-IV Diagnostic Criteria For Substance Dependence

DSM-IV Diagnostic Criteria For Substance Dependence The DSM-IV defines AOD addiction as "substance dependence," and describes the diagnostic criteria as a maladaptive pattern of substance use, leading to clinically significant impairment or distress, as manifested by three or more of the following occurring at any time in the same 12-month period:

1. Tolerance, as defined by either of the following:
  - The need for markedly increased amounts of the substance to achieve intoxication or desired effect.
  - Markedly diminished effect with continued use of the same amount of the substance.
2. Withdrawal, as manifested by either of the following:
  - The characteristic withdrawal syndrome for the substance.
  - The same (or closely related) substance is taken to relieve or avoid withdrawal symptoms.
3. Taking the substance often in larger amounts or over a longer period than was intended.
4. A persistent desire or unsuccessful efforts to cut down or control substance use.
5. Spending a great deal of time in activities necessary to obtain or use the substance or to recover from its effects.
6. Giving up or reducing important social, occupational, or recreational activities because of substance use.
7. Continued substance use despite knowledge of having had a persistent or recurrent physical or psychological problem that was likely to have been caused or exacerbated by the substance.

Source: Adapted from American Psychiatric Association, 1994.

Once a condition has been diagnosed, a treatment plan can be developed that takes into account the severity of the patient's substance use disorder, the available treatment resources, and the patient's preferences. The American Society of Addiction Medicine (ASAM) has developed criteria and recommendations for patient placement in various levels and types of treatment (ASAM, 1991). Other criteria for placing patients in treatment have been developed by States and managed-care organizations. Some of those are reviewed in another TIP in this series, The Role and Current Status of Patient Placement Criteria in the Treatment of Substance Use Disorders.

If the assessment reveals that a patient has experienced AOD withdrawal in the past, this information can be used to estimate the severity of current withdrawal signs and symptoms.

## Postassessment Considerations

### Treatment Planning

The discussion below focuses on some issues specific to treatment planning for hospitalized trauma patients. A detailed discussion of treatment planning and treatment is beyond the scope of this TIP. Other TIPs in this series have addressed treatment for special populations including adolescents, pregnant women, offenders, persons with coexisting mental illness and substance abuse, persons with human immunodeficiency virus/acquired immunodeficiency syndrome (HIV/AIDS), and persons with opiate addictions.

A discussion of the effectiveness of brief interventions has been included at the end of this chapter. Some brief intervention strategies may be used in the hospital setting with patients who are recovering from injuries. Such interventions can help keep patients with AOD problems focused on the need for treatment and can motivate and prepare them for entering treatment.

Treatment planning, like assessment, employs a biopsychosocial approach. The entire range of AOD treatment options should be considered for the trauma patient, including inpatient AOD treatment, intensive outpatient treatment, outpatient treatment, residential treatment, family therapy, and so forth. Information pertaining to the patient's medical condition, as it relates to trauma, must be integrated into treatment planning and aftercare planning. Some patients, for example, will be taking prescribed analgesics, and pain management becomes an issue.

As discussed in Chapter 3, AOD abusers may display difficult behaviors. The assessment may document behaviors that can complicate medical, nursing, and psychiatric management of patients. Knowledge of these issues can sometimes help staff anticipate deviations from the normal hospital course.

For many trauma patients, posttrauma care will include ongoing rehabilitation and physical therapy. There may be a long period as an inpatient. Recommendation for AOD abuse treatment may coincide with these other therapies, and the patient's course of treatment will affect the type of AOD treatment that is most appropriate and possible. Continuing care should be anticipated and discussed in the early stages of treatment planning. This care can include participation in self-help groups and regular telephone contact with the counselor.

As discussed in Chapter 3, models are needed for providing effective AOD treatment to patients with cognitive impairments resulting from brain damage and patients with paralysis from spinal cord injuries. Special AA meetings or other support groups may offer help to patients and families.

If the patient is willing, the family should become involved in the treatment as soon as possible. Family issues are frequently pivotal in undertaking AOD abuse treatment. The traumatic injury is often a crisis for the family, as well as for the patient. It is a clear signal that help is needed, and it is an opportunity to get help. Family members are usually adversely affected by the AOD problems of the patient. They may have AOD problems themselves and may have mixed feelings about getting help for the patient. They may feel as helpless as the patient in doing something about the situation. The involvement of an AOD professional in addressing these issues can help them work toward a positive resolution. Contact with the family can be established only with appropriate consents. The process of obtaining these consents is described in Chapter 6 of this TIP.

## Role of the Primary Care Physician

American Medical Association policy guidelines describe the role of primary care physicians in handling substance abuse problems in patients (American Medical Association, 1979). Three different roles are defined. At the first level or role, all physicians with clinical responsibility should recognize AOD-caused dysfunction as early as possible and be aware of medical complications of AOD disorders. They should be able to assess and diagnose AOD disorders and to refer patients to appropriate sources of AOD treatment. At the second level are physicians who accept limited treatment responsibility, mainly to restore the individual to the point of being capable of participating in long-term AOD treatment. In this role, the physician assists the patient in achieving an AOD-free state and a long-term recoveries plan; the physician helps the patient learn about the nature of his or her disease.

At the third level are physicians who accept responsibility for long-term treatment of patients with AOD problems. These physicians acquire knowledge via training and experience in the treatment of AOD disorders, including pharmacological treatments. Such physicians establish a supportive, nonjudgmental relationship with the patient and establish conditions and limits of the therapy; the physician is available to the patient as needed for an indefinite period of recovery. Physicians periodically evaluate and update the recovery plan and involve the patient in various health, social, vocational, and spiritual support systems.

American Medical Association policy guidelines describe the role of primary care physicians in detecting and treating substance abuse problems in their patients or referring them for treatment.

## Brief Interventions

### The Effectiveness of Brief Interventions

Brief, empathic interventions that consist of even a single session can decrease consumption of alcohol and its adverse effects by 20 to 50 percent (Babor and Grant, 1992; Chick et al., 1985; Wallace et al., 1988). Research has found that when programs are implemented to identify problem drinking and drug use, physicians' behaviors change coincident with increased confidence in their own management skills (Wallace et al., 1988; Graham, 1991).

Brief, empathic interventions that consist of even a single session can decrease consumption of alcohol and its adverse effects by 20 to 50 percent.

Specific strategies and supporting research for such brief interventions are described in this section. The focus of research to date has been on reducing alcohol use. Although such interventions may be similarly effective in decreasing use of other drugs, more research is needed.

The earliest healthcare research on brief interventions for problem drinkers occurred in the emergency medical care setting, where personnel were concerned about how to facilitate referrals to AOD treatment (Chafetz, 1961; Chafetz et al., 1962). Without any intervention, investigators found that only 5 percent of those referred to a postdischarge appointment with an AOD specialist kept the appointment. A brief intervention strategy was implemented in which a specially trained counselor met briefly with the patient after emergency care was completed. The counselor discussed and evaluated the patient's drinking. An empathic approach that communicated respect, understanding, and caring was emphasized. Sixty-five percent of patients who received this brief intervention kept the followup appointment. In a replication of the study (Chafetz, 1968; Chafetz et al., 1964), the appointment completion rates were 6 percent for the control group (no intervention) and 78 percent for the group that received the intervention.

A study by Kristenson and associates (1983) in Sweden showed that simple, inexpensive, short-term interventions were effective in motivating patients to change their heavy drinking behaviors. In that study, levels of the liver enzyme gamma-glutamyltransferase (GGT) were measured in 8,859 men ages 46 to 53. Elevated levels were used to select heavy drinkers from this group. These subjects were offered monthly GGT tests and monthly medical check-ins with a nurse (quarterly with a physician). They were encouraged to lower their overall alcohol consumption. These interventions resulted in a significant decrease in the subjects' alcohol consumption and days absent from work because of illness, as well as lower GGT values over a period of 6 years.

A number of other clinical trials have examined the effectiveness of brief advice with problem drinkers. Bien and colleagues identified 10 such studies in healthcare settings in 14 countries (Bien et al., 1993). In Great Britain, the impact of a physician's advice on the reduction of excessive alcohol consumption was demonstrated in a 12-month followup study of 909 heavy drinkers (Wallace et al., 1988). Participants were given general advice on smoking, exercise, and diet. The intervention group was also given information on the potentially harmful effects of their drinking and was provided a weekly diary to record alcohol use. Group members were shown a histogram comparing their weekly alcohol consumption with national norms, given a booklet on sensible drinking, and scheduled for followup visits. Twelve months later, the intervention group showed significant reductions in heavy drinking—in fact, a twofold greater reduction than the control group. There was no substantial change in smoking, exercise frequency, or weight reduction.

A multinational study for the World Health Organization on brief interventions with heavy drinkers had similar findings (Babor and Grant, 1992). This landmark study developed and tested brief-intervention protocols in 10 countries with diverse cultures and healthcare systems. (This project also developed the AUDIT screening test discussed earlier in this chapter and shown in Exhibit 4-3). The intervention protocols tested included simple advice (a 5-minute session on sensible drinking or abstinence), brief counseling (a 15-minute session and a self-help manual), and extended counseling (initial brief counseling and three or more monitoring visits). The findings upheld the positive results of other minimal intervention studies: alcohol consumption was significantly reduced, even in the group that received the briefest intervention.

Exhibit 4-3 Alcohol Use Disorder Identification Test (AUDIT)

Alcohol Use Disorder Identification Test (AUDIT)
1. How often do you have a drink containing alcohol? [ ] Never (0) [ ] Monthly or less (1) [ ] 2 to 4 times a month (2) [ ] 2 to 3 times a week (3) [ ] 4 or more times a week (4); 2. How many drinks containing alcohol do you have on a typical day when you are drinking? [ ] None (0) [ ] 1 or 2 (1) [ ] 3 or 4 (2) [ ] 5 or 6 (3) [ ] 7 or 9 (4) [ ] 10 or more (5); 3. How often do you have six or more drinks on one occasion? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 4. How often during the last year have you found that you were unable to stop drinking once you had started? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 5. How often during the last year have you failed to do what was normally expected of you because of drinking? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 6. How often during the last year have you needed a first drink in the morning to get yourself going after a heavy drinking session? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 7. How often during the last year have you had a feeling of guilt or remorse after drinking? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 8. How often during the last year have you been unable to remember what happened the night before because you had been drinking? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 9. Have you or someone else been injured as the result of your drinking? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); 10. Has a relative, friend, or a doctor or other health worker been concerned about your drinking or suggested you cut down? [ ] Never (0) [ ] Less than monthly (1) [ ] Monthly (2) [ ] Weekly (3) [ ] Daily or almost daily (4); Record the total of the specific items. [ ] A score of 8 or greater may indicate the need for a more in-depth assessment.

Source: Developed by the World Health Organization, AMETHYST Project, 1987 (Babor and Grant, 1989).

### Common Elements of Effective Brief Interventions

Research in healthcare settings supports the efficacy of using brief interventions for people identified as having addictive behaviors. Several common elements of effective brief interventions have been identified.

Bien and colleagues (1993) observed that many successful brief interventions focused on raising the patient's awareness of the problem and providing advice; they speculated that these approaches addressed critical conditions needed to instigate change. Miller and Sanchez (1993) enumerated six elements, commonly included in brief interventions, that have been shown to be effective. They are summarized by the acronym FRAMES: Feedback, Responsibility, Advice, Menu, Empathy, and Self-Efficacy (see Exhibit 4-8).

Exhibit 4-8 FRAMES: Elements of Brief Interventions

FRAMES: Elements of Brief Interventions

- FEEDBACK of personal risk or impairment. Most successful brief interventions provide clients with some form of feedback of the results of their AOD assessment.
- Emphasis on personal RESPONSIBILITY for change. Many brief interventions advise patients that drinking is their own responsibility and choice. The implicit or explicit message is that "What you do about your drinking is up to you." Perceived control has been recognized as an element of motivation for behavior change and maintenance (Miller, 1985).
- Clear ADVICE to change. Effective brief interventions contain explicit verbal or written advice to reduce or stop drinking. In fact, advice has been described as the essence of the brief intervention (Edwards et al., 1977).
- A MENU of alternative change options. Self-help resources have typically described an array of alternative strategies for reducing drinking. Effective brief interventions seldom advise a single approach, but rather a general goal or a range of options. Presumably, this broad approach increases the likelihood that an individual will find an approach appropriate to his or her situation.
- Therapeutic EMPATHY as a counseling style. Successful interventions have emphasized a warm, reflective, empathic, and understanding approach. No reports of effective brief counseling contain aggressive, authoritarian, or coercive elements.
- Enhancement of client SELF-EFFICACY or optimism. It is common in brief interventions to encourage self-efficacy for change, rather than emphasizing helplessness or powerlessness. Optimism regarding the possibility of change is often embedded in effective motivational counseling.
- Ongoing followup. In addition to these six elements, effective use of brief intervention often includes repeated followup visits. At least two studies have found that a reduction in drinking occurs after the first followup visit (Elvy et al., 1988; Heather et al., 1987). However, even without the benefit of repeated followup, studies consistently document the occurrence of marked behavior change immediately following the brief intervention.

Source: Adapted from Miller and Sanchez, 1993.

A landmark, multinational study for the World Health Organization on brief interventions with heavy drinkers found that alcohol consumption was significantly reduced, even in the group that received the briefest intervention -- 5 minutes of simple advice.

### Client-Centered Interviewing

As discussed in the commentary by Bien and colleagues (1993), current medical training emphasizes technology-based, physician-centered decisionmaking. Excluded from most training are skills in effective listening, negotiating with patients, and dealing with ambivalence. Physicians may learn to blame patients for lack of compliance and for denial, whereas their own interviewing and negotiating styles may greatly influence a patient's compliance and outcome.

The patient's motivation is an important factor in changing behavior. A healthcare professional can encourage motivation with client-centered interviewing that makes the patient an active participant in setting the goals to be achieved. The elements of the interview should be empathic and warm, yet provide objective feedback of the data obtained from screening and assessment. Aggressive confrontation or coercion will not achieve the objective of encouraging the patient to change.

Researchers additionally recommend that the interview incorporate the following elements (Delbanco, 1992; Miller and Rollnick, 1991; Ockene et al., 1988; Rollnick et al., 1992):

- Assessing the patient's readiness for change
- Identifying barriers to recovery
- Identifying patient strengths
- Reinterpreting past experiences in light of current medical consequences
- Negotiating a followup plan
- Providing hope.

#### Assessing Readiness to Change

A key reason for the effectiveness of brief interventions may be that they affect a person's motivation for change. Once such motivation has been aroused, the patient may proceed to change negative behavior with little or no assistance.

A 12-item Readiness to Change Questionnaire was developed for use in brief, opportunistic interventions with excessive drinkers (Rollnick et al., 1992). It includes such items as "Sometimes I think I should cut down on my drinking" and "Drinking less alcohol would be pointless for me" and provides a short and convenient measure of the patient's willingness to change. It was designed with the nonspecialist (in AOD treatment) in mind. When the instrument was used as a screening tool in general hospitals, it was found to be a good predictor of a patient's motivation for change (Heather et al., 1993).

Copies of the questionnaire and a users' manual are available on request from Nick Heather, National Drug and Alcohol Research Centre, University of New South Wales, P.O. Box 1, Kensington, NSW 2033, Australia.

Aggressive confrontation or coercion will not achieve the objective of encouraging the patient to change.

### Referral

The healthcare professional can refer the patient to appropriate treatment programs or counselors or recommend a self-help group. Studies suggest that such referrals can lead to successful treatment yielding long-term benefits (Elvy et al., 1988). A variety of specific practices increase the likelihood of a successful referral. These practices include the following, in addition to the FRAMES elements outlined above:

- Telephoning for a specific appointment with the patient present
- Following up with an encouraging note or phone call
- Arranging for the patient to be seen without delay.

If an immediate appointment is not available, some evaluation and intervention should be provided immediately, rather than have the client wait until an appointment is available.

## Summary

There is encouraging evidence that the course of addictive behaviors can be effectively altered by intervention strategies that are feasible within relatively brief contact situations. These strategies can be implemented by nurses, nurses' aides, counselors, psychologists, social workers, physicians, and other professionals. Some strategies found to achieve results include

- Empathic interview and negotiation techniques, including negotiation of a followup plan
- Provision of hope for change
- Clinician call to arrange an initial appointment for followup care
- Followup letter or phone call from clinician
- Policy of seeing the patient immediately rather than putting him or her on a waiting list
- Verbal or written contracts with the clinician
- Goal setting for cessation of drug or alcohol use
- Instructional and self-help reading materials
- Completion of weekly AOD use diaries
- Role-play procedures to prepare patient for treatment.

Perhaps the most important element of brief interventions is a caring style on the part of the clinician, including an emphasis on the client's personal responsibility for recovery, and encouragement that the client already has sufficient personal resources to accomplish the needed behavior change.