# Appendix D—Field Reviewers

- Maryann Amodeo, M.S.W., Ph.D.
- Director, Alcohol and Drug Institute for Policy, Training, and Research
- Associate Professor
- School of Social Work
- Boston University
- Boston, Massachusetts

- Everett Atkins, M.A., C.D.C.
- Certification Specialist, Certification Section
- Division of Alcohol and Substance Abuse
- Department of Social and Health Services
- Olympia, Washington

- Edward Bernstein, M.D.
- Associate Professor, Emergency Medicine and Public Health
- Boston City Hospital
- Department of Emergency Medicine
- West Newton, Massachusetts

- Robert Brewer, M.D., M.S.P.H.
- Medical Epidemiologist, Division of Unintentional Injury Prevention
- National Center for Injury Prevention and Control
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Margaret Kent Brooks, J.D.
- Consultant
- Montclair, New Jersey

- H. Blair Carlson, M.D., M.S.P.H.
- Medical Director, Chemical Dependency Treatment Services
- Kaiser Permanente, Colorado Region
- Denver, Colorado

- Arthur W.K. Chan, Ph.D.
- Senior Research Scientist, Research Institute on Addictions
- New York State Office of Alcoholism and Substance Abuse Services
- Buffalo, New York

- Richard Christensen, P.A., C.A.S.
- Director of Medical Services
- Valle del Sol
- Phoenix, Arizona

- William Clark, M.D.
- Medical Director, Addiction Resource Center
- Mid-Coast Hospital
- Bath, Maine

- Dorynne Czechowicz, M.D.
- Associate Director for Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Elizabeth Danto, A.C.S.W.
- Adjunct Assistant Professor
- Hunter College and School of Social Work
- City University of New York
- New York, New York

- David S. Davis, M.D., J.D.
- Attending Physician, Emergency Department
- North Arundel Hospital
- Glen Burnie, Maryland

- Andrew DiBartolomeo, M.D., M.B.A., F.A.C.E.P.
- Medical Director
- Apple Creek Developmental Center
- Apple Creek, Ohio

- Martin C. Dout, M.D.
- Vice President of Medical Services
- Lutheran General Behavioral Health
- Lutheran General Hospital
- Park Ridge, Illinois

- Christopher W. Dunn, Ph.D.
- Psychologist, Trauma Prevention Project
- Harborview Medical Center
- Seattle, Washington

- Michael F. Fleming, M.D., M.P.H.
- Associate Professor, Office of Alcohol and Addiction Studies
- Department of Family Medicine and Practice
- University of Wisconsin - Madison Medical School
- Madison, Wisconsin

- Richard J. Frances, M.D.
- Director, Department of Psychiatry
- Hackensack Medical Center
- Hackensack, New Jersey

- Roman Frankel, B.S., N.C.A.C. II, C.E.A.P.
- President/Executive Director
- New Start Inc.
- West Bloomfield, Michigan

- Steven Freng, M.S.W.
- Systems Chief, Division of Alcoholism and Substance Abuse Services
- Seattle-King County Department of Public Health
- Seattle, Washington

- Elizabeth A. Garcia, C.M.S.W.
- Director of Managed Care
- Pinal Gila Behavioral Health Association
- Apache Junction, Arizona

- Larry M. Gentilello, M.D.
- Assistant Professor, Department of Surgery
- Harborview Medical Center
- Seattle, Washington

- Andrea P. Goodman
- Project Administrator
- Office of Substance Abuse
- Augusta, Maine

- Marc Hertzman, M.D.
- Medical Director, Department of Psychiatry
- North Arundel Hospital
- Glen Burnie, Maryland

- Norman G. Hoffmann, Ph.D
- Vice President
- New Standards Inc.
- St. Paul, Minnesota

- ReneJ S. Holleran, R.N., Ph.D., C.E.N., C.C.R.N., C.F.R.N.
- Chief Flight Nurse/Emergency Clinical Nurse Specialist
- University of Cincinnati
- Milford, Ohio

- Vivian H. Jackson, A.C.S.W.
- Clinical Social Work Associate
- National Association of Social Workers
- Washington, D.C.

- Linda Kaplan, M.A., C.A.E.
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Christine L. Kasser, M.D.
- Medical Director
- Baptist Recovery Center
- Memphis, Tennessee

- Christoph R. Kaufmann, M.D., M.P.H.
- Trauma Surgery Consultant, Division of Trauma and Emergency Medical Systems
- Bureau of Health Resources Development
- Health Resources and Services Administration
- Rockville, Maryland

- John J. Kelly, D.O., F.A.C.E.P.
- Assistant Professor, Department of Emergency Medicine
- Medical College of Pennsylvania
- Philadelphia, Pennsylvania

- Thomas W. Kozlowski, A.C.S.W.
- Associate Director, Office of Mental Health Accreditation Services
- Joint Commission on Accreditation of Healthcare Organizations
- Oakbrook Terrace, Illinois

- Michael S. Kuntzelman, M.D.
- Deputy Medical Director
- Arizona Center for Clinical Management
- Tucson, Arizona

- Karen E. Larson, R.N., B.S.N.
- Assistant Director, Division of Alcohol and Drug Abuse
- North Dakota Department of Human Services
- Bismarck, North Dakota

- Lawrence S. Linder, M.D.
- Assistant Chief, Emergency Department
- North Arundel Hospital
- Glen Burnie, Maryland

- John Loiselle, M.D.
- Assistant Professor of Pediatric Emergency Medicine
- Medical College of Pennsylvania
- St. Christopher's Hospital for Children
- Philadelphia, Pennsylvania

- Carole A. Madden, R.N., B.S.N., C.D.
- North Arundel Hospital
- Glen Burnie, Maryland

- Jan Mashman, M.D.
- Medical Director
- Assistant Clinical Professor
- Department of Neurology
- Yale Medical School
- Brookfield, Connecticut

- John R. Miles, M.P.A.
- Substance Abuse Coordinator, Office of the Director
- Division of STD/HIV Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Richard Morin, M.D.
- President
- Morin Medical Services, P.C.
- Ann Arbor, Michigan

- Daniel A. Nauts, M.D.
- Medical Director, Addiction Medicine Center
- Montana Deaconess Medical Center
- Great Falls, Montana

- James M. Oher, C.S.W., C.E.A.P.
- Managing Director
- J.M. Oher & Associates
- Chappaqua, New York

- Mary A. O'Shea, R.N., M.N., C.C.R.N.
- Nursing Informatics Coordinator
- Department of Veterans Affairs Medical Center
- Kansas City, Missouri

- Ted Parran, Jr., M.D., F.A.C.P.
- Assistant Clinical Professor of Medicine
- Case Western Reserve University School of Medicine
- Cleveland, Ohio

- Kent A. Questad
- Clinical Assistant Professor, Psychology
- Department of Rehabilitation Medicine
- Harborview Medical Center
- Seattle, Washington

- Jeanne Rigaud, M.S., A.D.C.
- Program Manager, Division/Substance Abuse
- Behavioral Health Services
- New Mexico Department of Health
- Santa Fe, New Mexico

- Peter O. Rostenberg, M.D. B Chair
- Co-Chair, Trauma Committee
- American Society of Addiction Medicine
- Internal Medicine, Addiction Medicine
- New Fairfield, Connecticut

- Susan D. Ryan
- Chief, Emergency Medical Services Division
- Office of Enforcement and Emergency Services
- National Highway Traffic Safety Administration
- U.S. Department of Transportation
- Washington, D.C.

- Paul N. Samuels
- Director/President
- Legal Action Center
- New York, New York

- Marguerite T. Saunders
- Commissioner
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, New York

- Dena J. Seiden, Ph.D.
- Medical Ethicist
- Medical Ethics Consulting Services
- New York, New York

- Cherin Silver, Esq.
- Philadelphia, Pennsylvania

- Harvey Skinner, Ph.D.
- Professor and Chairman, Department of Behavioral Science
- Faculty of Medicine
- University of Toronto
- Toronto, Ontario, Canada

- Carl A. Soderstrom, M.D., F.A.C.S.
- Director, Office of Physician Education
- Staff, Department of Surgery/Traumatology
- R. Adams Cowley Shock Trauma Center
- University of Maryland Medical Center
- Baltimore, Maryland

- Marilyn Sawyer Sommers, R.N., Ph.D.
- Associate Professor, College of Nursing and Health
- University of Cincinnati
- Cinncinati, Ohio

- Richard T. Suchinsky, M.D.
- Associate Director, Addictive Disorders and Psychiatric Rehabilitation
- Department of Veterans Affairs
- Washington, D.C.

- Herbert L. Thornhill, M.D.
- Director, Department of Rehabilitation Medicine
- Harlem Hospital Center
- New York, New York

- Julian A. Waller, M.D., M.P.H.
- Professor of Medicine Emeritus, Department of Medicine
- University of Vermont
- Burlington, Vermont

- Richard L. Weiss, Ph.D.
- Psychology/Neuropsychology
- Birmingham, Michigan

- Robert S. Whitney, M.D.
- Head of Medical Services, Clinical Research Center
- Research Institute on Addictions
- Buffalo, New York