# Appendix C—Federal Resource Panel

- John Ambre, M.D., Ph.D.
- Director, Department of Toxicology and Drug Abuse
- American Medical Association
- Chicago, Illinois

- James Callahan, D.P.A.
- American Society of Addiction Medicine
- Chevy Chase, Maryland

- Sandra M. Clunies, M.S., N.C.A.D.C.
- Government Project Officer, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Dorynne Czechowicz, M.D.
- Associate Director for Medical and Professional Affairs
- Medical Affairs Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, Maryland

- Herman I. Diesenhaus, Ph.D.
- Review Administrator
- Extramural Activities Review
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- David L. Griffith, M.S., M.Ed., R.N.
- Public Health Advisor, Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Linda Kaplan, M.A., C.A.E.
- Executive Director
- National Association of Alcoholism and Drug Abuse Counselors
- Arlington, Virginia

- Peter O. Rostenberg, M.D. Chair
- Co-Chair Trauma Committee
- American Society of Addiction Medicine
- Internal Medicine, Addiction Medicine
- New Fairfield, Connecticut

- Paul R. Van Ostenberg, D.D.S., M.S.
- Director, Department of Standards
- Joint Commission on Accreditation of Healthcare Organizations
- Oakbrook Terrace, Illinois