# Appendix B—Glossary of Medical Terms

:

analgesia:: (the state of) insensibility to pain without loss of consciousness.

analgesic:..: characterized by or producing analgesia; an agent for producing analgesia.

arteriosclerosis:..: a chronic disease characterized by abnormal thickening and hardening of the arterial walls with resulting loss of elasticity.

bradycardia:..: relatively slow heart action.

CBC:..: complete blood count.

cerebrovascular accident:..: an occurrence of sudden damage to the brain or to the brain and the blood vessels surrounding it.

chemical paralysis:..: complete or partial loss of function induced by chemical agents, usually involving power of motion or sensation in any part of the body.

cognition:..: cognitive mental processes. Conscious intellectual activity such as thinking, reasoning, remembering, imagining, or learning.

colon:..: the large intestine from the cecum to the rectum.

CT scans:..: computerized tomography. Radiography (x-ray) in which three-dimensional images are constructed by computer from cross-sectional images.

debridement:..: the surgical removal of damaged, dead, or contaminated tissue.

decubitus ulcer:..: an ulceration of tissue deprived of nutrition by prolonged pressure; a bedsore.

electrolyte:..: a substance that when dissolved in a suitable solvent, such as water, or when fused becomes an ionic conductor... Maintaining appropriate electrolyte balance is necessary for regulating certain vital bodily functions.

endotracheal intubation:..: placement of a tube into the trachea to keep it open so that air passes to and from the lungs.

hematest:..: a test that checks for small quantities of blood in the stool, the presence of which can indicate gastrointestinal bleeding.

hypertension:..: abnormally high arterial blood pressure.

hypotension:..: abnormally low arterial blood pressure.

gamma-glutamyl transferase (GGT):..: a liver enzyme; an elevated level of GGT can indicate chronic alcohol use.

intracranial pressure monitoring:..: monitoring pressure within the skull; increased pressure can indicate a brain injury.

ischemic bowel:..: an insufficient blood supply to bowel tissue caused by obstruction or disruption of the inflow of blood (as in narrowing of arteries by spasm, disease, or injury).

mean corpuscular volume:..: the volume of the average red blood cell in a given blood sample; a larger than normal volume can be an indicator of chronic alcohol use.

myocardial infarction:..: damage to or death of heart tissue, usually as a result of the obstruction of local blood flow.

perforated septum:..: characterized by one or a series of perforations in a dividing wall or membrane, especially between bodily spaces or masses of soft tissue, such as the nasal septum, the bowel, and the eardrum.

peritoneal lavage:..: therapeutic washing of the smooth transparent membrane lining the abdominal cavity... This procedure can avoid the necessity of open abdominal surgery to detect internal bleeding following a traumatic injury.

physiatrist:..: a physician who specializes in physical medicine or physical therapy and rehabilitation.

right lower quadrant:..: the right side of the human body below the waist; one of the four segments into which the body can be divided.

tachycardia:..: rapid heartbeat, whether physiological (as after exercise) or pathological (resulting from disease).

trauma injury:..: tissue damage caused by external force or violence.

vascular headache:..: moderate to severe head pain resulting from constriction or dilatation of intracranial blood vessels.

vasoactive:..: affecting the blood vessels, especially in respect to the degree of their relaxation or contraction.

vital signs:..: signs of life; specifically, the pulse rate, respiratory rate, body temperature, and blood pressure.