# Appendix A -- Bibliography

Adams, P.F., and Benson, V. Current estimates from National Health Interview Survey, 1991. In: Vital Health Statistics, 1992. Rockville, Maryland, National Institutes of Health. 1993.
American Bar Association Center on Children and the Law. A Judicial Benchbook on Drugs and Families. Washington, D.C.: State Justice Institute. 1991.
American College of Surgeons. Advanced Trauma Life Support Manual. Chicago: American College of Surgeons. 1992.
American College of Surgeons, Committee on Trauma. Resources for Optimal Care of the Injured Patient. Chicago: American College of Surgeons. 1993.
American Medical Association. AMA Guidelines for Physician Involvement in the Care of Substance-Abusing Patients. Chicago: American Medical Association. 1979.
American Medical Association. Screening for Alcohol and Other Drug Use in Trauma Patients (House of Delegates, Resolution A91). Chicago: American Medical Association. 1991.
American Medical Association, Council on Scientific Affairs. Alcohol and the driver. Journal of the American Medical Association. 1986;255:522-527.
American Medical Association, Council on Scientific Affairs. Helmets and preventing motorcycle- and bicycle-related injuries. Journal of the American Medical Association. 1994;272:1535-1538.
American Psychiatric Association. Diagonistic and Statistical Manual of Mental Disorders, Fourth Edition. Washington, D.C.: American Psychiatric Association. 1994.
American Society of Addiction Medicine. Core Benefit for Primary Care and Specialty Treatment and Prevention of Alcohol, Nicotine and Other Drug Abuse and Dependence. Washington, D.C.: American Society of Addiction Medicine. 1993.
American Society of Addiction Medicine. Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders. Washington, D.C.: American Society of Addiction Medicine. 1991.
American Society of Addiction Medicine. Public Policy Statement on Addiction Medicine and Health Insurance Reform. Washington, D.C.: American Society of Addiction Medicine. 1992.
American Society of Addiction Medicine. Public Policy Statement on Trauma and Chemical Misuse/ Dependency. Washington, D.C.: American Society of Addiction Medicine. 1991.
Anda, R.F., Williamson, D.F., and Remington, P.L. Alcohol and fatal injuries among U.S. adults: findings from the NHANES I epidemiological follow-up study. Journal of the American Medical Association. 1988;260:2529-2532.
Annegers, J.F., Grabow, J.D., Kurland, L.T., and Laws, E.R. Jr. The incidence, causes, and secular trends of head trauma in Olmstead County, Minnesota, 1935-1974. Neurology. 1980.
Arnstein-Kerslake, G.W., and Peck, R.C. A Typological Analysis of California DUI Offenders and DUI Recidivism Correlates. Report No. 100. Sacramento: California Department of Motor Vehicles. 1985.
Babor, T.F., and Grant, M. From clinical research to secondary prevention: international collaboration in the development of the Alcohol Use Disorders Identification Test (AUDIT). Alcohol Health and Research World. 1989;13:371-374.
Babor, T.F., and Grant, M. Project on Identification and Management of Alcohol-Related Problems. Report on Phase II: A Randomized Clinical Trial of Brief Interventions in Primary Health Care. Geneva, Switzerland: World Health Organization. 1992.
Bailey, D.N. Drug use in patients admitted to a university trauma center: results of limited (rather than comprehensive) toxicology screening. Journal of Analytical Toxicology. 1990;14:22-24.
Bailey, D.N. Plasma cocaethylene concentrations in patients treated in the emergency room or trauma unit. American Journal of Clinical Pathology. 1993;99:123-127.
Baker, S.P. Injuries: the neglected epidemic. Journal of Trauma. 1987.
Barry, K.L., and Fleming, M.F. Computerized administration of alcoholism screening tests in a primary care setting. Journal of the American Board of Family Practice. 1990;3:93-98.
Bien, T.H., Miller, W.R., and Tonigan, J.S. Brief interventions for alcohol problems: a review. Addiction. 1993.
Bikle, D.D., Genant, H.K., Cann, C., Recker, R.R., Halloran, B.P., and Strewler, G.J. Bone disease in alcohol abuse. Annals of Internal Medicine. 1985;103:42-48.
Blancoe, L.J., and Faigin, B.M. The Economic Cost of Motor Vehicle Crashes, 1990. Washington, D.C.: National Highway Traffic Safety Administration. 1991.
Bottoms, S., Martier, S., and Sokol, R. Refinements in screening for risk drinking in reproductive-aged women: the NET results. Alcoholism: Clinical and Experimental Research. 1989;13:339.
Brookoff, D., Campbell, E.A., and Shaw, L.M. The underreporting of cocaine-related trauma: drug abuse warning network reports vs. hospital toxicology tests. American Journal of Public Health. 1993;83:369-371.
Brookoff, D., Cook, C.S., Williams, C., and Mann, C. Testing reckless drivers for cocaine and marijuana. The New England Journal of Medicine. 1994;331:518-22.
Brown, M.L. The national economic burden of cancer: an update. NCI Special Report, December 5. 1990.
Brown, R., and Rounds, L. Conjoint screening questionnaires for alcohol and drug abuse: two pilot studies. Unpublished study, 1991.
Buchsbaum, D.G., Buchanan, R.G., Centor, R.M., Schnoll, S.H., and Lawton, M.J. Screening for alcohol abuse using CAGE scores and likelihood ratios. Annals of Internal Medicine. 1991;115:774-777.
Bush, B., Shaw, S., Cleary, P., Delbanco, T.L., and Aronson, M.D. Screening for alcohol abuse using the CAGE questionnaire. American Journal of Medicine. 1987;82:231-235.
California Department of Alcohol and Drug Programs. Evaluating Recovery Services: The California Drug and Alcohol Assessment (CALDATA). Sacramento: California Department of Alcohol and Drug Programs. 1994.
Chafetz, M.E. A procedure for establishing therapeutic contact with the alcoholic. Quarterly Journal of Studies on Alcohol. 1961.
Chafetz, M.E. Research in the alcohol clinic: an around-the-clock psychiatric service of the Massachusetts General Hospital. American Journal of Psychiatry. 1968;124:1674-1679.
Chafetz, M.E., Blane, H.T., Abram, H.S., Clark, E., et al. Establishing treatment relations with alcoholics: a supplementary report. Journal of Nervous and Mental Disease. 1964;138:390-393.
Chafetz, M.E., Blane, H.T., Abram, H.S., Golner, J., et al. Establishing treatment relations with alcoholics. Journal of Nervous and Mental Disease. 1962;134:395-409.
Chang, G., and Astrachan, B.M. The emergency department surveillance of alcohol intoxication after motor vehicle accidents. Journal of the American Medical Association. 1988;260:2533-2536.
Chang, G., Astrachan, B.M., Weil, U., and Bryant, K. Reporting alcohol-impaired drivers: results from a national survey of emergency physicians. Annals of Emergency Medicine. 1992;21:284-290.
Chick, J., Lloyd, G., and Crombie, E. Counseling problem drinkers in medical wards: a controlled study. British Medical Journal. 1985;290:965-967.
Clark, D.E., McCarthy, E., and Robinson, E. Trauma as a symptom of alcoholism (editorial). Annals of Emergency Medicine. 1985;14:274.
Clark, R.F., and Harchelroad, F. Toxicology screening of the trauma patient: a changing profile. Annals of Emergency Medicine. 1991;20:151-153.
Colquitt, M., Fielding, L.P., and Cronan, J.F. Drunk drivers and medical and social injury. New England Journal of Medicine. 1987;371:1262-1266.
Cutler, S.F., Wallace, P.G., and Haines, A.P. Assessing alcohol consumption in general practice patients - a comparison between questionnaire and interview. Alcohol. 1988;23:441-450.
Cyr, M.G., and Wartman, S.A. The effectiveness of routine screening questions in the detection of alcoholism. Journal of the American Medical Association. 1988;259:51-54.
Delbanco, T. Enriching the doctor-patient relationship by inviting the patient's perspective. Annals of Internal of Medicine. 1992.
Dietz, P.E., and Baker, S.P. Drowning: epidemiology and prevention. American Journal of Public Health. 1974;64:303-312.
Dischinger, P.C., Soderstrom, C.A., and Shankar, B.S. The relationship between the use of alcohol and place of death in vehicular fatalities. In: Proceedings of the 32nd Annual Meeting: American Association of Automotive Medicine. 1988.:pp. 299-311.
Edna, T. Alcohol influence and head injury. Acta Chirurgica Scandinavica. 1982;148:209-212.
Edwards, G., Orford, J., Egert, S., Guthrie, S., et al. Alcoholism: a controlled trial of "treatment" and "advice.". Journal of Studies on Alcohol. 1977;38:1004-1031.
Elvy, G.A., Wells, J.E., and Baird, K.A. Attempted referral as intervention for problem drinking in the general hospital. British Journal of Addiction. 1988;83:83-89.
Ewing, J.A. Detecting alcoholism: the CAGE questionnaire. Journal of the American Medical Association. 1984;252:1905-1907.
Fleming, M.F., and Barry, K.L. A three-sample test of a masked alcohol screening questionnaire. Alcohol and Alcoholism. 1991;26:81-91.
Fullerton, D., Harvey, R., Klien, M., and Howell, T. Psychiatric disorders in patients with spinal cord injuries. Archives of General Psychiatry. 1981;28:1369-1371.
Gavin, D.R., Ross, H.E., and Skinner, H.A. Diagnostic validity of the Drug Abuse Screening Test in the assessment of DSM-III Drug Disorders. British Journal of Addiction. 1989;84:301-307.
Geller, G., Levine, D.M., Mamom, J.A., Moore, R.D., et al. Knowledge, attitudes, and reported practices of medical students and house staff regarding the diagnosis and treatment of alcoholism. Journal of the American Medical Association. 1989;261:3115-3120.
Gentilello, L.M., Duggan, P., Drummond, D., Tonnesen, A., et al. Major injury as a unique opportunity to initiate treatment in the alcoholic. American Journal of Surgery. 1988;156:558-561.
Gentilello, L.M., Kobean, R., Walker, A., Moore, E., et al. Acute ethanol intoxication increases the risk of infection following penetrating abdominal trauma. Journal of Trauma. 1993;34:669-675.
Graham, A. Screening for alcoholism by lifestyle risk assessment in a community hospital. Archives of Internal Medicine. 1991;151:958-964.
Haddon, W. Jr. Advances in the epidemiology of injuries as a basis for public policy. Public Health Reports. 1980;95:411-421.
Heather, N., Campion, P.D., Neville, R.G., and MacCabe, D. Journal of the Royal College of General Practitioners. 1987;37:358-363.
Heather, N., Rollnick, S., and Bell, A. Predictive validity of the Readiness to Change Questionnaire. Addiction. 1993.
Heinemann, A.W., Donohoe, R., Keen, M., and Scholl, S. Alcohol use by persons with recent spinal cord injuries. Archives of Physical and Medical Rehabilitation. 1988;69:619-624.
Heyman Consultants. Screening and brief intervention of illicit drugs, alcohol and tobacco use in the primary care setting. Unpublished report. Ridgefield, Connecticut: Heyman Consultants. 1994.
Holder, H.D. Alcoholism treatment and total health care utilization and costs: a four-year longitudinal analysis of federal employees. Journal of the American Medical Association. 1986;256:1456-1460.
Holder, H.D., and Blose, J.O. The reduction of health care costs associated with alcoholism treatment: a 14-year longitudinal study. Journal of Studies on Alcohol. 1992.
Holder, H.D., Longabaugh, R., Miller, W.R., and Rubonis, A.V. The cost effectiveness of treatment for alcoholism: a first approximation. Journal of Studies on Alcohol. 1991.
Holder, H.D., and Shachtman, R.H. Estimating health care savings associated with alcoholism treatment. Alcoholism: Clinical and Experimental Research. 1987;11:66-73.
Honkanen, R., and Smith, G.S. Impact of acute alcohol intoxication on the severity of injury: a cause-specific analysis of non-fatal trauma. Injury. 1990;21:353-357.
Horn, J.L., Skinner, H.A., Wanberg, K., and Foster, F.M. The Alcohol Use Questionnaire (ADS). Toronto, Canada: Drug Addiction Research Foundation. 1984.
Horn, J.L., Wanberg, K.W., and Foster, F.M. Guidelines for understanding alcohol use and abuse. The Alcohol Use Inventory. Baltimore, MD: Psych Systems. 1985.
Hutchinson, D.T., McClinton, M.A., Wilgis, E.F.S., and Frisk-Millner, N. Drug and alcohol use in emergency hand patients. Journal of Hand Surgery. 1992.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Washington, D.C.: National Academy Press. 1990.
Johnson, D.L., O'Malley, P., and Bachman, J. Drug Use Among American High School Seniors, College Students, and Young Adults, Volume I. Rockville, Maryland: National Institute on Drug Abuse. 1994.
Jones, G.A. Substance abuse treatment for persons with brain injuries. NeuroRehabilitation. 1992.
Jurkovich, G.J., Rivara, F.P., Gurney, J.G., Seguin, D., et al. Effects of alcohol intoxication on the initial assessment of trauma patients. Annals of Emergency Medicine. 1992;21:704-708.
Kramer, T.H., and Housington, D. Use of AA and NA in the treatment of chemical dependencies of traumatic brain injury survivors. Brain Injury. 1992;6:81-88.
Kraus, J.S. Delivery of substance abuse services during spinal cord injury rehabilitation. NeuroRehabilitation. 1992;2:45-51.
Kraus, J.S., Peek, C., McArthur, D.L., and Williams, A. The effect of the 1992 California motorcycle helmet use law on motorcycle crash fatalities and injuries. Journal of the American Medical Association. 1994;272:1506-1511.
Kristenson, H., Ohlin, H., Hulten-Nosslin, M.B., Trell, E., et al. Identification and intervention of heavy drinking in middle-aged men: results and follow-up of 24-60 months of long-term study with randomized controls. Alcoholism: Clinical and Experimental Research. 1983;7:203-209.
Loiselle, J.M., Baker, M.D., Templeton, J.M. Jr., Schwartz, G., et al. Substance abuse in adolescent trauma. Annals of Emergency Medicine. 1993;22:1530-1534.
Lopez, F. Confidentiality of Patient Records for Alcohol and Other Drug Treatment. Technical Assistance Publication Series 13. Rockville, Maryland: Center for Substance Abuse Treatment. 1994.
Lowenfels, A.V., and Miller, T.T. Alcohol and trauma. Annals of Emergency Medicine. 1984;13:1056-1060.
Lowenstein, S.R., Weissberg, M.P., and Terry, D. Alcohol intoxication, injuries, and dangerous behaviors - and the revolving emergency department door. Journal of Trauma. 1990;30:1252-1258.
MacKenzie, E.J., Morris, J.A., Jr., and Edelstein, S.L. Effect of pre-existing disease on length of hospital stay in trauma patients. Journal of Trauma. 1989;29:757-765.
Martinez, R. Injury prevention: a new perspective. Journal of the American Medical Association. 1994;272:1541-1542.
Marzuk, P.M., Tardiff, K., Leon, A.C., Stajic, M., et al. Prevalence of recent cocaine use among motor vehicle fatalities in New York City. Journal of the American Medical Association. 1990;263:250-256.
Maull, K. Alcohol abuse: its implications in trauma care. Southern Medical Journal. 1982;75:794-798.
Mayfield, D.G., McLeod, G., and Hall, P. The CAGE questionnaire: validation of a new alcoholism screening instrument. American Journal of Psychiatry. 1974;131:1121-1123.
McLellan, B.A., Vingilis, E., Liban, C.B., Stoduto, G., et al. Blood alcohol testing of motor vehicle crash admissions at a regional trauma unit. Journal of Trauma. 1990;30:418-421.
Miller, W.R. Motivation for treatment: a review with special emphasis on alcoholism. Psychological Bulletin. 1985;98:84-107.
Miller, W.R., and Rollnick, S. Motivational Interviewing: Preparing People to Change Addictive Behavior. New York, Guilford Press. 1991.
Miller, W.R., and Sanchez, V.C. Motivating young adults for treatment and lifestyle change. In: Howard, G., ed. Issues in Alcohol Use and Misuse by Young Adults. Notre Dame, Indiana: University of Notre Dame Press. 1993.
Mishkin, G., and Sparadeo, F.R. Effects of substance use on recovery from TBI. Paper presented at the annual meeting of the National Head Injury Foundation, Los Angeles. 1991.
Moore, R., Bone, L., Geller, G., Mamon, J., et al. Prevalence, detection, and treatment of alcoholism in hospitalized patients. Journal of the American Medical Association. 1989;261:403-407.
National Center for Injury Prevention and Control. Ten Leading Causes of Injury Death in the United States. Atlanta: Centers for Disease Control and Prevention. 1991.
National Head Injury Foundation. Facts About Traumatic Brain Injury. Washington, D.C.: National Head Injury Foundation. 1994.
National Institute on Alcohol Abuse and Alcoholism. Alcohol Alert, No. 3. 1989.
National Institute on Alcohol Abuse and Alcoholism. Alcohol and Health: Eighth Special Report to the U.S. Congress. Washington, D.C.: Department of Health and Human Services, September. 1993.
National Institute on Drug Abuse. Problem oriented screening instruments for teenagers. In: Rahdert, E., ed. The Adolescent Assessment/Referral System Manual. Rockville, Maryland: National Institute on Drug Abuse. 1990.
National Research Council. Accidental Death and Disability: The Neglected Disease of Modern Society. Washington, D.C.: National Academy Press. 1966.
National Research Council. Injury in America: A Continuing Public Health Problem. Washington, D.C.: National Academy Press. 1985.
New York State Office of Alcoholism and Substance Abuse Services. Health Care Intervention Services: The Third Formative Report. New York: OASAS. 1993.
Ockene, J., Quirk M., Goldberg, R., Kristeller J., et al. A residents' training program for the development of smoking intervention skills. Archives of Internal Medicine. 1988;148:1039-1045.
Parkinson, D., Stephenson, S., and Phillips, S. Head injuries: a prospective, computerized study. Canadian Journal of Surgery. 1985;28:79-83.
Perper, J.A., Twerski, A., and Wienand, J.W. Tolerance at high blood alcohol concentrations: a study of 110 cases and review of the literature. Journal of Forensic Studies. 1986;31:212-221.
Prytz, H., and Melin, T. Identification of alcoholic liver disease or hidden alcohol abuse in patients with elevated liver enzymes. Journal of Internal Medicine. 1993;223:21-26.
Ravenholt, R.T. Addiction mortality in the United States, 1980: tobacco, alcohol, and other substances. Population and Development Review. 1984;10:697-724.
Ray W.A., Griffin, M.R., and Downey, W. Benzodiazepines of long and short elimination half life and the risk of hip fracture. Journal of the American Medical Association. 1989;262:3303-3307.
Regier, D.A., Farmer, M.E., Rae, D.S., Locke, B.Z., et al. Comorbidity of mental disorders with alcohol and other drug abuse: results from the Epidemiologic Catchment Area (ECA) study. Journal of the American Medical Association. 1990;264:2511-2518.
Reyna, T.M., Hollis, H.W., and Hulsebus, R.C. Alcohol-related trauma: the surgeon's responsibility. Annals of Surgery. 1985;201:194-197.
Rice, D.P., MacKenzie, E.J., et al. Cost of Injury in the United States: A Report to Congress. San Francisco: Institute for Health and Aging, University of California, and Injury Prevention Center, Johns Hopkins University. 1989.
Rimel, R.W., Giordani, B., Barth, J.T., and Jane, J.A. Moderate head injury: completing the clinical spectrum of brain trauma. Neurosurgery. 1982.
Rimel, R.W., and Jane, J. Characteristics of the head-injured patient. In Rosenthal, M., Griffith, E., Bond, M., and Miller, J., eds. Rehabilitation of the Head-Injured Adult. Philadelphia: F.A. Davis. 1983.
Rivara, F.P., Gurney, J.G., Ries, R.K., Seguin, D.A., et al. A descriptive study of trauma, alcohol, and alcoholism in young adults. Journal of Adolescent Health. 1992;13:663-667.
Rivara, F.P., Jurkovich, G.J., Gurney, J.G., Seguin, D., et al. The magnitude of acute and chronic alcohol abuse in trauma patients. Archives of Surgery. 1993a;128:907-913.
Rivara, F.P., Koespsell, T.D., Jurkovich, G.J., Gurney, J.G., et al. The effects of alcohol abuse on readmission for trauma. Journal of the American Medical Association. 1993b.
Rivara, F.P., Mueller, B.A., Fligner, C.L., Luna, G., et al. Drug use in trauma victims. Journal of Trauma. 1989;29:462-470.
Rollnick, S., Heather, N., Gold, R., and Hall, W. Development of a short "readiness to change" questionnaire for use in brief, opportunistic interventions among excessive drinkers. British Journal of Addiction. 1992;87:743-754.
Ross, H.E., Gavin, D.R., and Skinner, H.A. Diagnostic validity of the MAST and the Alcohol Dependence Scale in the assessment of DSM-III alcohol disorders. Journal of Studies on Alcohol. 1990;51:506-513.
Ross, H.E., Glaser, F.B., and Germanson, T. The prevalence of psychiatric disorders in patients with alcohol and other drug problems. Archives of General Psychiatry. 1988;45:1023-1031.
Rovner, S. Broken hips: a danger for elderly who fall. Washington Post, Health. 1994.
Russell, M., Martier, S.S., Sokol, R.J., Jacobson, S., et al. Screening for pregnancy risk-drinking: TWEAKING the tests (abstract). Alcohol: Clinical and Experimental Research. 1991;15:368.
Rutherford, W.H. Diagnosis of alcohol ingestion in mild head injuries. Lancet. 1977;1:1021-1022.
Rutledge, R., and Messick, W.J. The association of trauma death and alcohol use in a rural state. Journal of Trauma. 1992;33:737-742.
Saunders, J., Aasland, O., Babor, T., de la Fuenta, J., Grant M. Development of the Alcohol Use Disorders Identification TEST (AUDIT): WHO collaborative project on early detection of persons with harmful alcohol consumption. II. British Journal of Addiction. 1993.
Schuckit, M.A. Drug and Alcohol Abuse: A Clinical Guide to Diagnosis and Treatment, Third Edition. New York and London: Plenum Medical Book Company. 1989.
Schwartz, R.H. Alcohol, drugs, and head injury (letter). Pediatrics. 1986;78:1169.
Selzer, M.L. The Michigan Alcoholism Screening Test: the quest for a new diagnostic instrument. American Journal of Psychiatry. 1971;127:1653-1658.
Selzer, M.L., Vinokur, A., and Van Rooijen, L. A self-administered Short Michigan Alcoholism Screening Test (SMAST). Journal of Studies on Alcohol. 1975;36:117-126.
Simel, D.L., and Feussner, J.R. Blood alcohol measurements in the emergency department: who needs them?. American Journal of Public Health. 1988;78:1478-1479.
Sims, D.W., Bivins, B.A., Obeid, F.N., Horst, H.M., et al. Urban trauma: a chronic recurrent disease. Journal of Trauma. 1989;29:942-957.
Skinner, H.A. Drug Abuse Screening Test. Addictive Behavior. 1982;7:363-371.
Skinner, H.A. Early identification of addictive behaviors using a computerized life style assessment. In: Baer, J., Marlett, G., and McMahon, R., eds. Addictive Behaviors Across the Lifespan: Prevention, Treatment and Policy Issues. Newbury Park, California: Sage. 1993:pp. 88-111.
Skinner, H.A., Holt, S., Schuller, R., Roy, J., et al. Identification of alcohol abuse using laboratory tests and a history of trauma. Annals of Internal Medicine. 1984;101:847-851.
Sloan, E.P., Zalenski, R.J., Smith, R.F., Sheaff, C.M., et al. Toxicology screening in urban trauma patients: drug prevalence and its relationship to trauma severity and management. Journal of Trauma. 1989;29:1647-1653.
Sobell, L.C., and Sobell, M.B. Self-report issues in alcohol abuse: state of the art and future directions. Behavioral Assessment. 1990;12:77-90.
Soderstrom, C.A., and Cowley, R.A. A national alcohol and trauma center survey: missed opportunities, failures of responsibility. Archives of Surgery. 1987;122:1067-1071.
Soderstrom, C.A., Dailey, J., and Kerns, T. Alcohol and other drugs: an assessment of testing and clinical practices in U.S. trauma centers. Journal of Trauma. 1994a;36:68-73.
Soderstrom, C.A., Dischinger, P.C., Smith, G.S., McDuff, D.R., et al. Psychoactive substance dependence among trauma center patients. Journal of the American Medical Association. 1992;267:2756-2759.
Soderstrom, C.A., Kerns, T.J., and Dischinger, P.C. RAC Shock Trauma Center and National Study Center for Trauma and EMS. Unpublished study. 1994b.
Soderstrom, C.A., Trifillia, A.L., and Shankar, B.S. Marijuana and alcohol use among 1023 trauma patients: a prospective study. Archives of Surgery. 1988;123:733-737.
Sokol, R.J., Martier, S.S., and Ager, J.W. The T-ACE questions: practical prenatal detection of risk-drinking. American Journal of Obstetrics and Gynecology. 1989;160:863-870.
Solomon, D.A., and Malloy, P.F. Alcohol, head injury, and neuropsychological function. Neuropsychology Review. 1992.
Solomon, D.A., and Sparadeo, F.R. Effects of substance abuse on persons with traumatic brain injury. NeuroRehabilitation. 1992.
Sparedeo, F.R. 1994.
Sparadeo, F.R., and Gill, D. Effects of prior alcohol use on head injury recovery. Journal of Head Trauma Rehabilitation. 1989;4:75-82.
Sparadeo, F.R., and Gill, D. Risks of alcohol use after head injury. Paper presented at the annual meeting of the American Psychological Association, Atlanta, August 12-16. 1988.
Stover, S.L., and Fine, P.R. Spinal Cord Injuries: The Facts and Figures. Birmingham: University of Alabama at Birmingham. 1986.
Swenson, W.M., and Morse, R.M. The use of the Self-Administered Screening Test (SAAST) in a medical center. Mayo Clinic Proceedings. 1975;50:204-208.
Teasdale, G., and Jennett, B. Assessment of coma and impaired consciousness: a practical scale. Lancet. 1974;2:81-84.
Thal, E.R., Bost, R.O., and Anderson, R.J. Effects of alcohol and other drugs on traumatized patients. Archives of Surgery. 1985;120:708-712.
Wallace, P., Cutler, S., and Haines, A. Randomized controlled trial of general practitioner intervention in patients with excessive alcohol consumption. British Medical Journal. 1988;297:663-668.
Wallace, P., and Haines, A. The use of a questionnaire in general practice to increase the recognition of patients with excessive alcohol consumption. BMJ. 1985;290:1949-1593.
Waller, J.A. Diagnosis of alcoholism in the injured patient. Paper presented at an NIAAA conference on Post-Injury Treatment of Patients With Alcohol-Related Trauma. Washington, D.C.: Department of Health and Human Services. 1988.
Waller, J.A. Identification of problem drinking among drunken drivers. Journal of the American Medical Association. 1967;200:114-120.
Waller, J.A. Injury as disease. Accident Analysis and Prevention. 1987;19:13-20.
Waller, J.A. Methodologic issues in hospital-based injury research. Journal of Trauma. 1988;28:1632-1636.
Waller, J.A. Nonhighway injury fatalities: the roles of alcohol and problem drinking, drugs, and medical impairment. Journal of Chronic Disease. 1972.
Waller, J.A. The physician's role in preventing alcohol-related injuries. Journal of the American Medical Association. 1988a;260:2561-2562.
Waller, P.F., Stewart, J.R., Hansen, A.R., Stutts, J.C., et al. The potentiating effects of alcohol on driver injury. Journal of the American Medical Association. 1986;256:1461-1466.
Walsh, D.C., Hingson, R.W., Merrigan, D.M., Levenson, S.M., et al. A randomized trial of treatment options for alcohol-abusing workers. New England Journal of Medicine. 1991.
Waterson, E., and Murray-Lyon, I. Are the CAGE questions outdated?. British Journal of Addiction. 1988;83:1113-1115.

### Other Authorities

Confidentiality of Alcohol and Drug Abuse Patient Records. 42 C.F.R. Part 2
52 Fed. Reg. 21796 (1987)
United States v. Eide, 875 F.2d 1429 (9th Cir. 1989)