# Consensus Panel

Co-Chairs
- Peter A. Selwyn, M.D., M.P.H.
- Associate Director, The AIDS Program
- Associate Professor of Medicine and Epidemiology and Public Health
- School of Medicine
- Yale University
- New Haven, Connecticut
- Steven L. Batki, M.D.
- Associate Clinical Professor, Substance Abuse Services
- Department of Psychiatry
- University of California
- San Francisco General Hospital
- San Francisco, California

Facilitators
- Robert H. Hodge, M.S.W., C.S.W., L.C.D.C.
- Director of Social Work
- Houston Therapies
- Houston, Texas
- Clara Yvonne Jones, M.D.
- Medical Consultant
- New York State Department of Health
- New York, New York
- Eldoris J. Mason, R.N., M.S.
- President and CEO
- Behavior Research and Action in the Social Sciences Foundation
- Chicago, Illinois
- Patricia Perez-Arce, Ph.D.
- Director, Mission Integrated Service Center
- Division of Mental Health and Substance Abuse
- San Francisco Department of Public Health
- Assistant Clinical Professor, Department of Clinical Psychology
- University of California
- San Francisco, California
- Jeffrey H. Samet, M.D., M.A., M.P.H.
- Assistant Professor of Medicine, Section of General Internal Medicine
- Boston University School of Medicine
- Boston, Massachusetts

Workgroup Members
- Lynn Boyle, L.C.S.W., A.C.S.W.
- Director of Social Services
- Alexian Brothers/Bonaventure House
- Chicago, Illinois
- Carolyn Barley Britton, M.D.
- Assistant Professor of Clinical Neurology
- College of Physicians and Surgeons
- Columbia University
- New York, New York
- Vivian B. Brown, Ph.D.
- Chief Executive Officer
- Prototypes, A Center for Innovation in Health, Mental Health, and Social Services
- Culver City, California
- Robert Paul Cabaj, M.D.
- Medical Director, Substance Consultation Abuse Service
- Department of Psychiatry
- San Francisco General Hospital
- San Francisco, California
- Maureen Deely, R.N.
- AIDS Outreach and Education
- STD/HIV Prevention Program
- Division of Communicable Disease and Epidemiology
- Montgomery County Health Department
- Silver Spring, Maryland
- James L. Hadler, M.D., M.P.H.
- Chief, Epidemiology Section
- State Epidemiologist
- Connecticut Department of Health Services
- Hartford, Connecticut
- Margaret A. Piasecki, E.D., P.A.
- Executive Director
- Nevada Treatment Center
- Las Vegas, Nevada
- Melvin I. Pohl, M.D.
- Medical Director, Substance Abuse Services
- Behavioral Healthcare Options
- Las Vegas, Nevada
- John E. Rawls, M.D.
- Medical Director, Bushwick Clinic
- Addiction Research and Treatment Corporation
- Brooklyn, New York
- Stephan Jon Sorrell, M.D. (Deceased)
- Medical Director, Substance Abuse Program
- St. Luke's/Roosevelt Hospital Center
- New York, New York
- Donald Storms, C.D.A.C, C.H.I.V.C., N.I.D.A.T.O.T., C.S.A.T.-T.O.T.
- Director of the Early Intervention Program
- New York City Department of Health
- Brooklyn, New York
- Fatima Zafar, M.D.
- Vice President of Clinical Services
- Economic Opportunity Family Health Center
- Miami, Florida