# Appendix I - Federal Resource Panel

- James R. Allen, M.D.
- Director, National AIDS Program Office
- Office of the Assistant Secretary of Health
- Washington, D.C.

- Duiona Baker, M.P.H.
- Public Health Advisor, Quality Assurance and Evaluation Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Suzanne Baranik
- Public Health Advisor
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Bernard M. Branson, M.D.
- Medical Epidemiologist, Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Jim Brennan
- Staff Associate
- National Association of Social Workers
- Washington, D.C.

- Anita Brown, Ph.D.
- Assistant Policy Director, Training and Research
- Practice Directorate
- American Psychological Association
- Washington, D.C.

- Barry Brown, Ph.D.
- Acting Director, Division of Epidemiology and Prevention Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- Dorynne Czechowicz, M.D.
- Associate Director, Medical Affairs Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- Walter L. Faggett, M.D.
- National Medical Association
- Washington, D.C.

- Raymond Fowler, Ph.D.
- Chief Executive Officer
- American Psychological Association
- Washington, D.C.

- Sander G. Genser, M.D., M.P.H.
- Acting Chief, Clinical Medicine Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- John Gregrich
- Acting Assistant Deputy for Treatment
- Office of National Drug Control Policy
- Executive Office of the President
- Washington, D.C.

- Claudia Hart
- Interim Director, Office of Psychiatric Services
- American Psychiatric Association
- Washington, D.C.

- Harry W. Haverkos, M.D.
- Acting Director, Division of Clinical Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- Christopher H. Hayden
- Chief, Program Support Section Program
- Services Branch
- Division of TB Elimination
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Warren Hewitt
- Acting Director, Division of Clinical Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Ruth H. Carlsen Kahn, R.N., D.N.Sc.
- Health Manpower Education Specialist
- Health Resources and Services Administration
- Division of Medicine
- Rockville, Maryland

- Saul M. Levin, M.D., M.P.A.
- President
- Access Consulting International, Inc.
- Washington, D.C.

- David C. Lewis, M.D.
- Association for Medical Education and Research in Substance Abuse
- Center for Alcohol and Addiction Studies
- Providence, Rhode Island

- George Lewis
- Senior Public Health Advisor
- United States Public Health Service
- Rockville, Maryland

- Anna Marsh, Ph.D.
- Associate Director for Evaluation, Office of Applied Studies
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Wendell McConnell, M.D.
- Chief, HIV/Linkage Branch
- Division of Clinical Programs
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- John R. Miles, M.P.A.
- Acting Chief, Program Operations Branch
- Division of STD/HIV Prevention
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Lucille C. Perez, M.D.
- Associate Director for Medical and Clinical Affairs
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- John Poundstone, M.D.
- American Association of Public Health Physicians
- Lexington, Kentucky

- Margaret Salinger, M.S.N., R.N., C.A.R.N.
- Head Nurse, National Nurses Society on Addiction
- Coatesville Veterans Administration
- Medical Center
- Audubon, Pennsylvania

- Jack Stein, L.C.S.W., A.C.S.W.
- Director
- Center for HIV/Substance Abuse Training
- Arlington, Virginia

- Sylvia D. Trent, R.N., M.S.A.
- Public Health Analyst
- Health Resources and Services Administration
- Rockville, Maryland

- Gloria Weissman
- Deputy Director, Office of Science Epidemiology
- Bureau of Health Resources Development
- Health Resources and Services Administration
- Rockville, Maryland

- Cecilia Douthy Willis, Ph.D.
- National Black Alcoholism and Addictions Council
- Washington, D.C.

- Randy Wykoff, M.D.
- Food and Drug Administration
- Rockville, Maryland