# Appendix G—National HIV/AIDS Organizations and Hotlines

## National Organizations

- AIDS Action Council
- Suite 700
- 1875 Connecticut Avenue, NW
- Washington, DC 20009

- AIDS National Interfaith Network
- 110 Maryland Avenue, NE
- Washington, DC 20002
- (202) 546-0807

- AIDS Policy Center for Children,
- Youth and Families
- 910 17th Street, NW
- Washington, DC 20036
- (202) 785-3564

- American Foundation for AIDS Research (AmFar)
- 733 3rd Avenue, 12th Floor
- New York, NY 10017
- (212) 719-0033
- Midwest Hispanic AIDS Coalition
- José Arrom
- Executive Director
- 1753 North Damen Avenue
- Chicago, IL 60647
- (312) 772-8195
- (312) 772-8484 Fax

- National Association of People With AIDS
- 1413 K Street, NW
- Washington, DC 20005
- (202) 898-0414

- National Community AIDS Partnership
- 1726 M Street, NW, Suite 501
- Washington, DC 20036
- (202) 429-2820

- National Episcopal AIDS Coalition
- Suite 509
- 2025 Pennsylvania Avenue, NW
- Washington, DC 20006
- (202) 628-6628

- National Leadership Coalition on AIDS
- 1730 M Street, NW, Suite 905
- Washington, DC 20036
- (202) 429-0930

- National Minority AIDS Council (NIAC)
- Paul Kawata
- Executive Director
- 300 I Street, NE, Suite 400
- Washington, DC 20002
- (202) 544-1076
- (202) 544-0378 Fax

- National Native American AIDS Prevention Center (NNAAPC)
- Ron Rowell
- Executive Director
- 3515 Grand Avenue, Suite 100
- Oakland, CA 94610
- (510) 444-2051
- (510) 444-1593 Fax

- National Pediatric HIV Resource Center
- 910 17th Street, NW, Suite 422
- Washington, DC 20036
- (202) 785-3509

- National Task Force on AIDS Prevention
- Randy Miller
- Executive Director
- 631 O'Farrell Street
- San Francisco, CA 94109
- (415) 749-6700
- (415) 749-6706 Fax

- National Women and HIV/AIDS Project
- P.O. Box 526-5853
- Washington, DC 20009
- (202) 526-5853

National Hotlines

AIDS Clinical Trials Information Service | 800-874-2572
CDC National AIDS Hotline Spanish | 800-344-7432 800-342-2437
HIV/AIDS Treatment Information Service | 800-448-0440
National AIDS Clearinghouse (database) | 800-458-5231
National Drug Abuse Hotline | 800-688-1777
National Hospicelink (Information on local facilities) | 800-331-1620
National Native American AIDS Hotline | 800-283-2437
National Sexually Transmitted Diseases Hotline/ASHA | 800-227-8922
Project Inform National Hotline (AIDS treatment information) | 800-822-7422
TTY/TDD Clinical Trials Hotline | 800-243-7012
The VIDEX (DDI) Reimbursement Helpline | 800-788-0123