# Appendix F—Standards of Care

Appendix F is not available in electronic format. To obtain a copy of the Standards of Care, order a hard copy of this TIP: Treatment for HIV-Infected Alcohol and Other Drug Abusers (15) by contacting the National Clearinghouse for Alcohol and Drug Information (NCADI), (800) 729-6686 or accessed at http://www.health. org/pubs/catalog/ordering.html. The reference number for this TIP is BKD163.