# Appendix J—Field Reviewers

- Duiona Baker, M.P.H.
- Public Health Advisor, Quality Assurance and Evaluation Branch
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services Administration
- Rockville, Maryland

- Jacqueline M. Bowens
- Clinical Coordinator
- Interventions -- Aids Research and Education
- Chicago, Illinois

- Lynn Boyle, L.C.S.W., A.C.S.W.
- Consultant
- Alexian Brothers/Bonaventure House
- Chicago, Illinois

- Karen Brown, B.A., C.A.C., C.D.C.
- Program Director
- Indiana Community AIDS Action Network
- Indianapolis, Indiana

- Alethia Carr, R.D., M.B.A.
- Coordinator, Childhood Lead Poisoning Prevention Program
- Michigan Department of Public Health
- Lansing, Michigan

- Dorynne Czechowicz, M.D.
- Associate Director, for Medical and Professional Affairs
- Medical Affairs Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- National Institutes of Health
- Rockville, Maryland

- Maureen C. Deely, R.N.
- Home Care Coordinator, AIDS Outreach and Education
- STD/HIV Prevention Program
- Division of Communicable Disease and Epidemiology
- Montgomery County Health Department
- Silver Spring, Maryland

- James M. Donagher
- HIV Coordinator, Office of Addiction Services
- Connecticut Department of Public Health and Addiction Services
- Hartford, Connecticut

- Kathy Donner
- Program Consultant, Social Rehabilitation Services
- Alcohol and Drug Abuse Services
- State of Kansas
- Topeka, Kansas

- Bruce E. Gould, M.D.
- Chief, Community Medicine
- Mount Sinai Hospital
- Hartford, Connecticut

- Jim Graham
- Executive Director
- Whitman-Walker Clinic
- Washington, D.C.

- William D. Hallum, M.F.C.C.
- Treatment and Recovery Division Manager
- San Luis Obispo County Drug and Alcohol Services
- San Luis Obispo, California

- A. Billy S. Jones, M.S.W., C.A.C.
- Project Director
- Macro International Inc.
- Calverton, Maryland

- Clara Yvonne Jones, M.D.
- Medical Director
- Samaritan Village Inc.
- Briarwood, New York

- Greg Lee
- Manager, AIDS Program
- Lexington-Fayette County Health Department
- Lexington, Kentucky

- Gary A. Lloyd, Ph.D., A.C.S.W.

- Professor and Coordinator, Institute for Research and Training in HIV/AIDS Counseling
- Tulane University School of Social Work
- New Orleans, Louisiana

- Malinda N. Lochner
- Public Health Advisor, Sexually Transmitted Diseases, HIV, and Prevention
- National Centers for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Gabrielle Montez Lopez, I.C.A.D.C.
- Adolescent Treatment Coordinator
- Prevention Education Evaluation Recovery
- Services, Inc.
- Evanston, Illinois

- Kay Malone, R.N., C.D., M.H.S.
- Nursing Supervisor, Projects Director
- Brandywine Counseling, Inc.
- Wilmington, Delaware

- Terrie L. Matthes, M.A., C.R.A.D.C.
- Program Director
- AIDS Foundation of Chicago
- Chicago, Illinois

- Francis A. McCorry, Ph.D.
- Director, HIV Services
- New York State Office of Alcoholism and
- Substance Abuse Services
- New York, New York

- John R. Miles, M.P.A.
- Substance Abuse Coordinator, HIV Prevention
- in Drug Users Unit
- Division of STD/HIV Prevention
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Janet L. Mitchell, M.D., M.P.H.
- Chief of Perinatology, Department of OB/GYN
- Harlem Hospital Center
- New York, New York

- Alvin Novick, M.D.
- Professor of Biology, Department of Biology
- Yale University
- New Haven, Connecticut

- Patrick G. O'Connor, M.D., M.P.H.
- Director, Primary Care Center
- Yale University School of Medicine
- New Haven, Connecticut

- Sheryl S. Palmer, M.A.
- Health Education Coordinator
- Treatment Alternatives for Special Clients, Inc.
- Chicago, Illinois

- Lucille C. Perez, M.D.
- Associate Director for Medical and Clinical Affairs
- Center for Substance Abuse Prevention
- Substance Abuse and Mental Health Services
- Administration
- Rockville, Maryland

- Margaret A. Piasecki, E.D., P.A.
- Executive Director
- Nevada Treatment Center
- Las Vegas, Nevada

- Barry Pillen, N.C.A.D.C.
- Assistant Director
- Division of Alcohol and Drug Abuse
- Department of Human Services
- Pierre, South Dakota

- Ron Powell, M.P.H.
- Executive Director
- National Native American AIDS Prevention Center
- Oakland, California

- Debra J. Powers, R.N., B.N.
- IDU/AIDS Treatment Specialist
- Bureau of Substance Abuse Services
- Madison, Wisconsin

- Margaret Salinger, R.N., M.S.N., C.A.R.N.
- Head Nurse/Supervisor, Substance Abuse Treatment
- Unit
- Coatesville Veterans Medical Center
- Audubon, Pennsylvania

- Jeffrey H. Samet, M.D., M.A., M.P.H.
- Assistant Professor of Medicine
- Boston University School of Medicine
- Boston City Hospital
- Boston, Massachusetts

- Peter A. Selwyn, M.D., M.P.H. CO-CHAIR
- Associate Director, Yale AIDS Program
- Associate Professor of Medicine, Epidemiology, and
- Public Health
- Yale University School of Medicine
- Yale-New Haven Hospital
- New Haven, Connecticut

- Patricia M. Simone, M.D.
- Deputy Chief, Program Services Branch
- Division of TB Elimination
- National Center for Prevention Services
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Michael Stein, M.D.
- Assistant Professor of Medicine
- Brown University
- Division of General Medicine
- Rhode Island Hospital
- Providence, Rhode Island

- Donald Storms, C.D.A.C., C.H.I.V.C., N.I.D.A.T.O.T.,

- C.S.A.T.-T.O.T.
- Director of the Early Intervention Program
- New York City Department of Health
- Brooklyn, New York

- Jerry Swank, B.S., M.B.A., N.C.A.C. II
- AIDS Programming Consultant
- State of Florida Alcohol and Drug Abuse Program
- Tallahassee, Florida

- Sari Trachtenberg, M.A., C.A.C.- Diplomate,
- N.C.A.D.C.
- Director of Professional Services
- Achievement Through Counseling and Treatment
- Philadelphia, Pennsylvania

- Katherine D. Yandle, M.S.W.
- Program Director, "The Bridge"
- South Carolina Department of Alcohol and Other
- Drug Abuse Services
- Columbia, South Carolina

- Fatima Zafar, M.D.
- Chief Executive Physician
- Economic Opportunity Family Health Center, Inc.
- Miami, Florida