# Consensus Panel

Chair
- Robert B. Aukerman, M.S.W.
- Director
- Alcohol and Drug Abuse Division
- Colorado Department of Health
- Peggy McGarry
- Senior Associate
- Center for Effective Public Policy
- Washington, D.C.

Facilitators
- Margaret Brooks, J.D.
- Consultant
- Montclair, New Jersey
- Jesse Jerry Jaramillo, B.S.
- Consultant
- Los Alamos, New Mexico
- George M. Little, M.A.
- Regional Director
- Delta Probation Region
- Tennessee Department of Corrections
- Memphis, Tennessee

Workgroup Members
- Gene R. Boyle, M.A.
- Director of Program Services
- Office of Drug and Alcohol Programs
- Pennsylvania Department of Health
- Harrisburg, Pennsylvania
- Mark Fontaine, M.S.W.
- Assistant Director
- Florida Alcohol and Drug Abuse Association
- Tallahassee, Florida
- Honorable Kathleen R. Gearin
- Judge, Second Judicial District
- St. Paul, Minnesota
- Leo Hayden, Jr., B.A.
- Director of Special Projects
- TASC, Inc.
- Chicago, Illinois
- Don Hogner, B.A.
- Chief Probation Officer (Ret.)
- Alameda County Probation Department
- Fresno, California
- Robbie Jackman, M.S.S.W.
- Assistant Commissioner
- Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health
- Nashville, Tennessee
- Tranice Diazell Jackson, M.D.
- Chief Physician, AMKC
- Montefiore/Rikers Island Health Services
- Manalapan, New Jersey
- Jane H. Martin, M.B.A.
- Director
- Risk Reduction Programs
- Division of Mental Health, Mental
- Retardation, and Substance Abuse
- Department of Human Resources
- Atlanta, Georgia
- Roger H. Peters, Ph.D.
- Assistant Professor
- Florida Mental Health Institute
- Department of Law and Mental Health
- University of South Florida
- Tampa, Florida
- Susan Powers, J.D.
- Deputy District Attorney
- Kings County District Attorney's Office
- Brooklyn, New York