# Chapter 3—The AOD Abuse Treatment System

The alcohol and other drug (AOD) abuse treatment system is just as complex and has as many nuances as the criminal justice system. Once its basic components are understood, it will be clear how different parts of the treatment system fit the needs of different individuals with specific AOD problems, within or outside of the justice system. The AOD abuse treatment field uses two terms interchangeably -- client and patient -- to refer to the individuals with the disorder.

It is important to understand that AOD abuse problems are the same wherever they occur: The disorder is the same among offenders in a correctional setting as among the law-abiding residents of any community in the country. Many offenders are farther along in the progression of the disease than persons who have not yet resorted to crime to financially support their addiction.

Alcohol and drug use disorder, or addiction, is a progressive disease, with increasing severity of biological, psychological, and social problems over time. If left untreated, the disease can be fatal. It is called a biopsychosocial disease because the client experiences problems in the biological, psychological, and social areas of life. Substance use disorder cannot be cured, but it can be arrested, and individuals can make the behavioral changes necessary to recover and stay in recovery. Relapse is a common feature of the disease, and it is not unusual for an individual to relapse following treatment and to alternate between treatment and relapse until lasting recovery is attained.

The progression of the severity of the disease can be depicted on a continuum that ranges from experimentation on one end to recovery or death on the other. So, too, the components of treatment comprise a continuum, starting with prevention at one end and progressing to intensive inpatient programs at the other. An important principle to treatment providers is to intervene at the earliest possible stage with the least restrictive form of appropriate treatment.

The normal practice in treatment is to provide the least restrictive form of treatment that can be expected to work with any particular client, depending on how far the client has progressed on the continuum from experimentation to use, abuse, severe illness, complete inability to function, and finally, overcoming denial or dying. This last stage has been viewed either as "bottoming out" -- in other words, being able to get no worse and "giving in" to the need for treatment -- or death. In recent years, as experience in providing treatment has accumulated, treatment providers have become able to successfully help abusers to have a "high bottom" -- that is, to recognize and overcome their denial and become motivated to do well in treatment at earlier stages in the disease's progression.

Several studies have suggested that mandated treatment is very effective. Intervention occurs earlier than it might have otherwise and the offender stays in treatment longer on average than the noncoerced client. Both early interventions and extended length of stay can contribute to better treatment outcomes. (See citations in the endnotes and bibliography.)

## The Goals of Treatment

The goals of treatment are to: 1) reduce incidence and prevalence of the chronic, progressive disease of addiction to alcohol and other drugs; 2) provide a system of services to assist people, their families, and communities in recovery from addiction, and 3) decrease the number of people who are at risk of becoming addicted. Treatment program personnel strive to support individuals, their families and significant others, and communities in the quest for recovery and healthful living. Services provided range from prevention and education through all stages of treatment, and include continuing care after the completion of treatment to prevent relapse, which is a prominent feature of the disease.

Secondary prevention and early intervention are part of the treatment continuum. Many people in need of treatment, for example, are at early stages in their disease, and one objective of their treatment is to prevent them from continuing to more advanced stages in the use of alcohol and other drugs. People at all stages of the disease can learn how to prevent its further progression.

Goals of AOD Abuse Treatment

- Reduce incidence and prevalence of addiction
- Provide a system of services to assist recovery from addiction
- Decrease the number of people at risk of becoming addicted

## The History of AOD Treatment

AOD treatment experienced changes during the 1960s and 1970s that had an impact on both the substance abuse treatment and criminal justice fields. Addictions treatment traditionally was provided by mental health professionals and focused on addictive behavior as a symptom of an underlying mental or emotional illness. Treatment was often received in psychiatric hospitals, with limited followup after discharge. Support for self-help or support groups, such as Alcoholics Anonymous (AA), was limited among treatment professionals. Individuals dealing with AOD-related problems often found their own way to AA or other groups only after repeated failures in treatment. For these individuals, treatment failures were further compounded by such issues as marital, employment, social, and legal problems related to their addiction.

Perhaps because of the limited number of treatment successes and the lack of recognition of the role of other related problems, professionals cited clients' lack of motivation as the most frequent reason for treatment failure. Because of this, treatment programs began to focus mostly on highly motivated voluntary clients. Motivation and voluntary enrollment became widely accepted as essential components for treatment success.

During the 1960s and 1970s, the emerging AOD treatment field began to develop different treatment approaches that focused beyond addictive diseases as disorders separate from mental illness. This view of addictions as separate diseases resulted in identification of specific treatments, which include long-term support and followup after treatment as essential components of treatment success. Therapeutic communities (TCs) were established, and professionals recognized community self-help groups such as AA.

TCs were viewed as alternatives to incarceration for offenders with AOD problems. TCs were among the first programs to treat drug-involved offenders who were either enrolled as involuntary clients or were given a choice between the TC or long-term incarceration. The long-term (1- to 2-year) treatment that TCs offered was designed to resocialize the individual who had developed a lifestyle of criminal behavior and addiction.

Shorter term residential treatment programs were also developed during this time, and many incorporated the 12 step model of AA. These programs were usually 30 to 60 days in length and emphasized learning how to live and maintain an alcohol- and drug-free lifestyle. A peer support philosophy was adopted and clients were encouraged to participate in AA during and after treatment. Followup treatment was offered to clients as needed and continued participation in AA was strongly encouraged to maintain sobriety and prevent relapse. Both TCs and short-term residential treatment programs continue to be viable options for treatment of AOD offenders.

The Federal Government gave new importance to addiction services through the creation in 1974 of the National Institute of Alcohol Abuse and Alcoholism (NIAAA) and the National Institute of Drug Abuse (NIDA), and emphasized the need for publicly supported addiction services. Resources were made available to States and community-based programs for the planning and implementation of prevention, intervention, and treatment services. These initiatives stimulated further expansion of treatment services and research into the nature of addictions.

The establishment of the Federal Law Enforcement Assistance Administration (LEAA) made resources available specifically for community-based treatment of AOD-involved offenders. One of the most successful models developed by LEAA was the Treatment Alternatives to Street Crime (TASC) program. Local TASC programs, administered by government agencies and private entities, provide screening, assessment, referral, and case management services to offenders, criminal justice systems, and AOD treatment systems. They provide the offender with support and accountability, monitor progress in AOD treatment, and make reports to the criminal justice system on compliance with sanctions.

These and other case management programs vary widely in the completeness of their screening and assessment and the breadth of their case management services. Most publicly funded treatment programs now offer counseling and testing for HIV infection, TB, and sexually transmitted diseases either onsite or by arrangement with a public health counseling and testing site. This is an essential component that must be provided by the criminal justice agency, the case management agency, or the treatment agency. Specific agreements are needed to ensure that communicable disease testing is completed.

Case management services can be provided by any of the agencies involved as well, but should be comprehensive. That is, the services must focus not only on participation in AOD treatment, but also on other services such as teaching literacy skills or providing job training or medical care. The substance-abusing offender is almost always an individual with many problems who requires multiple services.

Case management approaches have, however, demonstrated that AOD-dependent individuals who are involuntarily involved in treatment through the criminal justice system can be rehabilitated. Substance-abusing offenders who are provided case management services have longer treatment retention and completion rates, greater accountability, and lower recidivism rates than offenders not involved in similar case management and intensive supervision programs.

## Levels and Types of Treatment ^1^ 1. The section on levels and types of treatment is adapted from the Treatment Improvement Protocol Guidelines for the Treatment of Alcohol- and Other Drug (AOD)-Abusing Adolescents published by the Center for Substance Abuse Treatment.

Three major categories of treatment comprise the continuum: pretreatment services, outpatient treatment, and inpatient treatment (including residential care). Each category contains several subsets described as follows.

### Pretreatment Services

These services, which are not part of primary treatment, include primary prevention and early intervention.

Levels of AOD Abuse Treatment

- Pretreatment services
- Outpatient treatment
- Inpatient treatment

Primary prevention. These are services for persons who have not yet used AODs. Most primary prevention programs are in schools or the community, but some have been placed in correctional systems.

Early intervention. This may be a psychoeducational approach for people who have used AODs and are considered to be at high risk for AOD-related problems or have a history of AOD use, or it may be a screening process used to identify early AOD use problems. It is also appropriate for AOD-using persons who do not meet the diagnosis of an AOD use disorder. This approach may be used for ongoing evaluation for possible referral to a more intensive level of care. In some instances, early intervention can be used as short-term treatment for those whose AOD problem is of low severity.

### Outpatient Treatment

Also referred to as ambulatory care, outpatient treatment provides a broad range of services without overnight accommodation. Some of these services may be provided following inpatient or residential treatment or may be recommended after such treatment for continuing care.

Nonintensive outpatient treatment. This is AOD-focused treatment that includes professionally directed evaluation and treatment typically of less than 9 hours per week in regularly scheduled sessions. Nonintensive outpatient treatment may also address related psychiatric, emotional, and social issues. ^2^

2. The number of treatment hours is taken from the American Society of Addiction Medicine's (ASAM) Patient Placement Criteria for the Treatment of Psychoactive Substance Use Disorders and is offered as a working prototype. Some States have developed licensing regulations that dictate the number of hours associated with different levels of outpatient care. These hours, therefore, are only guidelines and may need to be altered to be consistent with State licensing regulations.

Intensive outpatient treatment. This is AOD-focused, professionally directed evaluation and treatment of 9-20 hours per week in a structured program. These programs may be evening programs, and frequently include some weekend programming.

Methadone maintenance treatment. This is a medically supervised outpatient treatment which provides counseling while maintaining the client on the drug methadone. This regimen is used primarily for heroin or other opiate addiction and provides a legitimate, closely monitored substitute for illegal or other prescription drugs. The client must be able to document at least a 2-year history of addiction to qualify for a methadone maintenance program.

Day treatment or partial hospitalization. This is AOD-focused, professionally directed evaluation and treatment of more than 20 hours per week in a structured program. This is the most intensive of the outpatient treatment options and can be used for treating patients who demonstrate the greatest degree of dysfunction but do not require inpatient or residential treatment. Evening and weekend programming may be included.

### Inpatient Treatment Options and Residential Care

Inpatient treatment options include intensive medical, psychiatric, and psychosocial treatment provided on a 24-hour basis. The continuum of residential care includes psychosocial care at the most intensive end and group living with no professional supervision at the least intensive end.

Medically monitored intensive inpatient treatment. ^3^ This level of care involves around-the-clock medical monitoring, evaluation, and treatment in an inpatient setting. It is used for patients who have acute and severe AOD use disorders and who may also have a coexisting medical or psychiatric problem. Such treatment generally involves a short-to-intermediate length of stay (7 to 45 days) and may include nonmedical or social model programs with variable lengths of stay.

3. Adapted from ASAM criteria.

Medically managed intensive inpatient treatment.3 This level of care involves around-the-clock, medically directed evaluation and treatment in an acute-care inpatient setting. This level of care is appropriate for the treatment of medical and psychiatric problems that may require biomedical treatment (such as life support) or secure services (such as locked units). Such treatment generally involves a short-to-intermediate length of stay (7 to 45 days).

Short-term nonhospital intensive residential treatment. This treatment is generally 21 to 45 days in length and is designed to teach the client how to live an AOD-free life and to provide motivation for the maintenance of such a lifestyle. Followup care on an outpatient basis and continued participation in peer support groups is recommended to maintain the recovery process begun in the residential setting.

Intensive residential treatment. This long-term (6 to 24 months) treatment model may be directed by an AOD treatment professional or may be medically directed. The model is similar to the therapeutic community model. It is appropriate for persons with multiple problems, especially those with dual disorders involving a personality and an AOD use disorder. The goal of psychosocial rehabilitation is always part of treatment.

Psychosocial residential care. This is a long-term (6 to 24 months), professionally directed, psychosocial care model. The model is also similar to the therapeutic community model and relies heavily on peer pressure as well as formal treatment to shape behavior. It is appropriate for persons with AOD abuse problems and concomitant disorders that do not require acute medical or psychiatric intervention. Persons compliant with psychiatric and other prescription medications may be appropriate for this level of care. The focus of care is on psychosocial rehabilitation.

Therapeutic community. The traditional therapeutic community is a long-term (15B24 months) rehabilitative model that relies primarily on peer staff (usually those who have been rehabilitated by the program) and on work as education and therapy. Other staff include treatment and mental health professionals and vocational and educational counselors. Because the aim of the therapeutic community is a global change in a person's lifestyle focused on the development of vocational, educational, and social skills, it is appropriate for persons with AOD abuse problems and chronic deficits in those areas. Most residents have been involved with the criminal justice system.

Halfway house. A halfway house is a residential, transitional living arrangement with minimal treatment in which residents are supervised by paid staff. Residents may work and receive education, training, or treatment in the surrounding community, although some treatment may be provided in the house. House responsibilities are shared, and rules must be followed. The length of stay may be limited or unlimited, contingent on the attainment of specific progress goals.

Group home living. This refers to a residential, transitional living situation without any specific treatment plan and minimal staff supervision. It is sometimes known as a three-quarter-way house. Residents may work and may receive education, training, or treatment in the community. House residents generally decide on admission of new residents. House responsibilities are shared, and the house is governed and run by its residents. The length of stay is generally unlimited as long as abstinence from AOD is maintained. The Oxford House model includes complete resident self-governance and self-sufficiency. The key to success in all such models is that the living situation is AOD-free and thus supports resident abstinence.

## Treatment Components

Programs vary depending on the individual needs of the client population and the availability of resources. Despite these variations, certain services are basic components of treatment for AOD-abusing persons. Sometimes a lack of resources imposes limits on services such as reducing length of stay, frequency of client contacts, and the availability of specialized skills and services. Programs that cannot provide all necessary components for alcohol and other drug treatment within their own facilities often establish ongoing linkages with other resources in the community that can provide them.

Preliminary screening and assessment should occur before the client enters any treatment program. The screening and assessment process is very important, and may be confused by members of the justice community with the classification process conducted by the agencies and institutions of the justice system. The purpose is the same: to determine the most appropriate response (whether clinical or correctional) to this individual. In addition, many probation and parole agencies use a "needs assessment" process that may look at similar client information. The analysis and the results of classification are very different, however.

In AOD abuse assessment, trained professionals or paraprofessionals collect information from the prospective client to determine whether the individual needs treatment and, if so, what level of treatment. Various types of screening and assessment instruments are available for this purpose. Following the assessment, in an ideal situation, the client will be placed in a treatment program that can best meet his or her needs.

This chapter lists and discusses components of treatment, many of which are core treatment components of an effective and comprehensive program. Detoxfication, which is a necessity for many patients, is often provided in a hospital under a physician's supervision prior to admission to a treatment program. In some cases, detoxification may be provided in a treatment program which is based in a or has access to a medical facility. Following an initial discussion of detoxification, components that are essential to the largest number of programs are described, followed by those that may be less essential. The extent to which a treatment component is essential will vary depending on the program. The components discussed below are:

- Detoxification
- Intake
- Screening
- Assessment
- Treatment planning
- Group therapy
- Family therapy
- Individual therapy
- Case management
- Drug testing
- Education sessions
- Emergency services
- Recreational activities and peer socialization
- Other specialized groups
- Relapse prevention and continuing care programs
- Multifamily groups
- Psychiatric interventions and dual diagnosis services
- Self-help groups
- Intervention
- Educational services (applicable to partial hospitalization and other programs which preclude attendance in school) and vocational training.

### Detoxification

Clients requiring detoxification may be treated in inpatient, residential, or outpatient settings. A client's particular psychosocial circumstances, personal characteristics, or addictions may mandate inpatient care. The process begins with an assessment of the client's need for detoxification and a determination of the most appropriate site for the provision of such treatment. Whether it is conducted on an outpatient, residential, or inpatient basis, detoxification should be monitored by appropriately trained personnel under the direction of a physician who understands the possible consequences of detoxification and has specific expertise in the management of withdrawal and abstinence.

### Intake

Intake counselors and other staff require training to ensure that treatment begins with the client's initial contact with the program. This first step in the treatment process should be to put the new client at ease and provide a brief overview of the program's parameters, such as length of treatment, treatment expectations, and program philosophy.

### Screening

The screening process begins at intake and extends through the conclusion of the assessment process. Screening often entails a brief interview and the administration of a standardized, validated screening questionnaire to identify the appropriate treatment level. It is at this point that the client and the evaluator answer the following questions: "What services are needed?" and "What program is the best match for the client?"

It is best if the screening process and initial decisions regarding the most appropriate treatment setting are made by an individual or agency that has no financial stake in a particular placement, thereby avoiding a conflict of interest or the appearance of one.

It is essential that screening for communicable diseases (HIV, TB, and sexually transmitted diseases) be an integral part of the initial screening and assessment process. This counseling and testing may be done on site by the criminal justice agency, an intermediate case management agency, or the AOD treatment agency. It may also be done by agreement at a public health counseling and testing site. Formal agreements are necessary to ensure that screening for communicable diseases is offered to all AOD-abusing offenders.

### Assessment

The assessment process involves a more in-depth evaluation of the client, lasting one or more sessions, including confirmation of the client's treatment referral and an individual and family psychosocial assessment. This step in the treatment process will give the clinical staff an understanding of the needs of the client, his or her motivation for treatment, and what substance use and other mental disorders may be present. The assessment provides a basis for developing an initial treatment plan.

In conducting the assessment, information should be obtained from multiple sources (such as the client, family members, significant others, counselors, probation officers, peers, and the client's employer), with the aid of multiple methods (such as self-administered questionnaires, interviews, and urinalysis). A comprehensive evaluation should address the following content areas: AOD use and treatment history, signs and symptoms of AOD abuse, intra- and interpersonal factors, environmental factors, medical and mental health status, educational status, employment status, and legal status.

The program's confidentiality regulations should be explained. The client will then be asked to sign a release of information and a form indicating consent to receive treatment. The program's grievance policies should also be explained, as well as how abstinence is monitored (for example, by urinalysis). Finally, the program's guidelines should be explained, as described below.

### Treatment Planning

#### Client Guidelines

Each client should receive a written set of program rules that represent the expectations of the treatment program. These rules may be presented in the form of a written contract that is signed by the client. The guidelines should include: 1) the requirement of abstinence during treatment, 2) rules for client behavior (such as respecting others and not being violent), and 3) the consequences of breaking rules. This process helps clients establish boundaries and understand that they are accountable for their behavior. Program staff are expected to abide by the same rules and code of behavior.

Each client should receive a written set of program rules that represent the expectations of the treatment program. These rules may be presented in the form of a written contract that is signed by the client.

#### Client Involvement

Early in treatment, clients should also be encouraged to outline their expectations of the program, defining what they expect to get from treatment. These goals can be incorporated into the treatment plan. The client's participation in the development of the treatment plan is very important to success and retention in treatment.

Other kinds of client expectations may be encouraged. For example, a program may support tobacco cessation among participants, but may choose not to mandate an absolute no-smoking policy for the individual in the first days of treatment.

#### Family Guidelines

Family members should be actively involved in all aspects of treatment whenever possible (including criminal justice system treatment programs), and need to be aware of expectations with regard to behavior and attitudes. Program staff should work collaboratively with the family and involved helpers. Family guidelines are one way to reinforce a family-centered treatment approach.

### Group Therapy

Group therapy involves peers in a group process that encourages them to address personal issues and the consequences of their AOD involvement. Unlike self-help groups, therapy groups are led by counselors. Group therapy is designed to solicit the involvement and support of others and to encourage healthy interaction. Through sharing, discussion, and problem solving, clients can begin to recognize denial and other signs of minimization and take responsibility for their AOD problems.

### Family Therapy

Families benefit from individual sessions, with and without the client present. Substance abuse often reflects family dysfunction and family tolerance of AOD use. For the client living with or dependent upon the family, recovery is difficult without the active involvement and support of the family. Family sessions address how the family must change its patterns of behavior and communication, values, and problem-solving strategies.

### Individual Therapy

Clients may need to receive individual therapy in addition to group and family therapy. Some clients are too withdrawn and socially uncomfortable to benefit from the group process, and they require individual therapy. Individual therapy helps clients: 1) cope with obstacles to utilizing group and family therapy and self-help groups, 2) discuss specific issues that they may not be ready to discuss in a group context, 3) improve the treatment alliance, and 4) help correct interpersonal difficulties and weaknesses.

### Case Management

Case management is a term used by both the criminal justice and AOD treatment systems because both systems have recognized the great need for coordinated services. For clarity, it would probably help to refer to "AOD case management" and "justice system case management," and, perhaps, "combined case management." The term, case plan, is used only by the justice system. Treatment plan is an AOD term. (Case management is further discussed in succeeding chapters of this TIP.)

Case management provides linkages with other service providers or between systems (such as the criminal justice system and the treatment program) in an effort to assist the client with his or her special needs. It is conducted by a designated case manager, who is responsible for coordinating all aspects of the treatment plan. Case management involves collaboration and networking with other agencies in the community to fill the gaps in services not offered by the treatment program. The range of supplementary services may include domestic violence services, medical care, dental care, housing assistance, mental health treatment, help in preparing Federal and State assistance applications, and childcare, as well as legal, educational, and vocational services. Helping the client and family negotiate the various service systems and coordinating the referral process are vital aspects of case management.

Many clients and families have several psychiatric, psychological, social, economic, and medical problems that will complicate recovery. Coordination, treatment planning, and decisions about how to divide tasks among various agencies require the attention and skill of case managers. Their involvement can help families and clients become more functional and more organized.

In the case of offender-clients, interagency case management becomes especially critical. Such clients are usually in treatment because of a court order and are typically under the continuing supervision of agents of one or more correction agencies. (For example, the offender may already be on probation or parole for one crime and on pretrial release status for another.) Client behavior while in treatment, including completing the treatment program, has significant consequences for the client's future. Expectations of the agencies involved, such as reporting requirements and appropriate responses to program rule violations, must be clarified and confirmed in writing. (This topic will be covered in detail in succeeding chapters.)

In the case of offender-clients, interagency case management becomes especially critical. Such clients are usually in treatment because of a court order and are typically under the continuing supervision of agents of one or more correction agencies.

The coordination of case management among various service providers may take the form of interagency agreements, including ongoing group case management meetings with agency representatives. Treatment programs should not wait for these systems to initiate such collaboration, but should begin the process themselves. The development of a coordinated case management protocol can enhance treatment effectiveness by decreasing the possibility that:

- Clients will manipulate the various systems providing services,
- Clients will perceive that the system "doesn't care" (since key concerns may have been insufficiently addressed), and
- The various systems will implement strategies that result in conflicting, duplicate, or contraindicated services.

Case management meetings can be particularly important when the client has other diagnoses in addition to AOD abuse. For example, if a client is HIV positive and has AOD problems, meetings with the agencies that provide medical care and support services may be necessary. Similarly, if there is a dual diagnosis -- AOD abuse and a mental disorder -- coordination between the treatment program and a mental health program is usually required. Few treatment programs can offer the needed mental health services themselves.

In all contacts with other agencies and individuals, there must always be respect for the client's right to confidentiality. This is particularly pertinent to issues of substance abuse, sexuality, and health problems such as HIV. (See Chapter 7 for a full discussion of the legal and ethical issues surrounding client confidentiality.)

### Drug Testing

Clients in treatment may minimize, deny, or otherwise distort the extent of their AOD use. To determine recent use, to be able to confront use during treatment, and to provide information about relapses, frequent urine drug screens may be helpful. Testing all clients at intake, random screening during treatment and continuing care, and designated screening when the therapist believes a client is deceptive about use are suggested. However, urinalysis screens measure only recent use, and do not provide information about the onset of substance abuse, the rate of use, or the quantity of use, except for recent levels. Periodic random testing may be required by the court or other legal authority for the offender-client.

### Education Sessions

Education sessions provide an opportunity for the client to learn about the effects of AOD abuse in a nonthreatening setting. Conducted like a classroom experience, these sessions often help people gain insight into their AOD problems and increase their motivation for self-care. They are also effective in decreasing denial and negative feelings about the treatment process.

The topics selected for education sessions will depend on the needs of the client population and the resource capabilities of the program. Referrals may be possible to other community programs for certain groups. Topics discussed in education groups can include the following:

- Medical effects and consequences of drug use and abuse
- The disease model of addiction (including the signs and symptoms)
- Introduction to 12-step programs (for example, step work, traditions, spirituality)
- Denial and other defense mechanisms
- Effects of substance abuse on the family, codependency, and issues of the children of alcoholics
- Thinking errors or illogical thinking patterns
- Human sexuality (When possible, there should be separate male and female groups. Issues pertaining to the problems experienced by gay men and lesbians may need special attention.)
- HIV/AIDS education
- Coping skills
- Communication skills.

### Emergency Services

Emergency service is an essential treatment component when working with AOD-abusing clients, some of whom may be suicidal or violent. Programs must make emergency services available by providing the on-call availability of medical and mental health professionals, crisis intervention, crisis management, and referrals to crisis and emergency shelter programs. It is not unusual for clients and families to experience great stress during the early phases of assessment and treatment. Crisis intervention can address these stresses and help the client and family (or significant others) make decisions that are likely to reduce the strain and permit the course of treatment to begin.

### Recreational Activities and Peer Socialization

It is important to explore alternative ways to have fun without the use of AODs. Mastering social situations and physical and mental challenges enhances clients' self-esteem and improves their repertoire of social and practical coping skills. Staff can participate in the activities, serving as positive role models for the clients. Many programs employ recreational therapists to coordinate these activities.

### Other Specialized Groups

Most persons in treatment have special life problems and individual needs. It is important for programs to be flexible, and to provide group treatment opportunities for them. The need for particular specialized groups will vary greatly depending on the nature of the client population. If a client has a particular need and a group is not available, it may be possible to address the issue in individual treatment or through referral services. Relevant topics for specialized groups are discussed below.

#### Cultural Groups

Programs must be responsive to the needs of clients from a variety of ethnic and cultural groups. Separate group meetings may be needed to address general as well as specific ethnic, racial, and cultural concerns. Specific issues might include:

- Racism
- Anger and frustration
- Cultural drug use patterns
- Discrimination
- Family patterns
- Rituals and ceremonies
- Negotiating service systems that may be insensitive to the needs of ethnic groups
- Positive aspects of "being different"
- Advocating for systemic change.

#### Specialized Services for Women

Many issues for substance-abusing women such as physical and sexual abuse cannot be adequately addressed in mixed-gender groups. These issues and others unique to substance-abusing women must be addressed in separate women's groups and in individual treatment. Pregnant women require counseling and courses concerning care of themselves and their unborn children, as well as prenatal care. (See the TIP Pregnant Substance-Abusing Women.)

#### Social Skill Building, Problem Solving, and Conflict Resolution

Social skill building and peer socialization take place in all groups as clients learn to talk about themselves and to listen to others. Prolonged AOD use often results in social skill deficits. Unless these deficits are overcome, clients will feel uncomfortable and out of place with peers who do not use AODs. Their primary area of personal reference will be drug knowledge and experience, making it difficult to maintain a clean and sober lifestyle.

Programs should encourage the development of new social skills or the enhancement of existing skills by presenting information, offering practice opportunities in group therapy, and incorporating naturally occurring social opportunities. Social skills to focus on might include: self-disclosure, giving and receiving positive and negative feedback, problem solving, conflict resolution and mediation, negotiation, assertiveness, coping with peer pressure, communication skills, understanding the cycle of violence, socializing and taking part in recreational activities without the use of alcohol and other drugs, and setting realistic personal goals. It is essential to offer conflict resolution groups when programs are in areas where there is a high rate of violence.

#### Human Immunodeficiency Virus (HIV)

As the HIV epidemic spreads among the AOD-abusing and offender populations, increasing numbers of clients will test positive for the HIV virus. Support groups for AOD abusers with HIV infection or full-blown AIDS are becoming a standard part of AOD abuse treatment programs. Other clients are dealing with concerns regarding significant others who have AIDS or who are HIV-infected and may need the support of a group.

#### Tobacco Cessation

Tobacco is an addictive substance that continues to be a significant public health problem. Specific behavioral and educational programs aimed at smoking cessation may be offered.

#### Independent Living Skills

Clients, especially those who will soon become independent, may require basic survival skills. Such skills include: money management, shopping, daily planning, job skills, finding an apartment, adjusting to roommates, developing supportive friendships and relationships, and using social support systems.

#### Diagnosis-Specific Group

Because of the high prevalence of psychiatric disorders among AOD-abusing clients, especially among offenders, these problems must be addressed as part of the treatment and relapse prevention conducted by specialized professionals. Ideally, clients sharing the same diagnosis should have access to their own group sessions. Funding, program priorities, and time limitations may prevent a program from providing this service, however. When these groups cannot be provided, it is incumbent on the program to utilize appropriate services in the community.

#### Health, Sexuality, STDs, and Contraceptives

To support the development of health promotion practices, programs should offer courses on special topics such as nutrition, STDs, contraceptives, and tuberculosis. These courses should be offered in addition to initial education concerning high-risk behaviors and initial counseling and testing.

#### Alumni Groups

Alumni groups are organized to exert positive peer pressure, to foster support and encouragement to stay in treatment for those who are struggling in early recovery, and to increase social opportunities and decrease isolation. These groups are especially helpful to outpatient programs, which, due to limitations on time and staffing, do not always have the same opportunity as residential programs to maintain consistent contacts with recovering clients.

#### Groups for Drug Dealers

Topics to be addressed in groups of drug dealers include: transferring short-term gratification to long-term goals (including vocational and educational objectives); recognizing that selling drugs involves entrepreneurial skills that can be redirected toward legal ventures; reinforcing alternatives to the hopelessness and despair that exist in some communities where the most visible role models are drug dealers; confronting the perception that society condones illegal drug activities and that dealers always "get away with it;" and learning techniques and skills to counteract pressure to continue dealing drugs.

#### Prostitution-Specific Group

Many programs have clients who engage in prostitution or "survival sex" to support their drug use. They may benefit from participation in a specialized support group. Prostitution, which may occur in males as well as females, is often intertwined with AOD use and is seen frequently among street persons who may be homeless.

#### Drug-Specific Groups

Patterns of drug abuse vary from community to community, year to year, and client to client. Certain substances, by their very nature, may require a specific focus. For instance, many communities are once again experiencing a problem with heroin abuse. Programs may wish to offer a specialized group for persons who use specific drugs or who have specific drug use patterns.

#### Gay and Lesbian Clients

Gay and lesbian clients may struggle with a range of issues that require attention in a specialized group.

#### Additional Specialized Groups

Additional groups may be defined by a wide range of unique factors or client characteristics. Such defining characteristics might include age, sexual victimization, medication prescribed, steroid use, having an eating disorder, grieving, and being children of alcoholics or codependent.

### Discharge, Continuing Care, and Relapse Prevention

At the completion of inpatient treatment, there should exist a structured and time-limited outpatient program and planning process that can assist the client in continuing recovery and obtaining ongoing support. This type of program is often referred to as a continuing care program (or aftercare). A smooth transition from inpatient treatment to discharge and then to continuing care requires coordination of goals and treatment, identification of personal signs of relapse, family involvement, and linkages to other services as necessary. The AOD abuse treatment program should be prepared to assist the client if relapse occurs. Relapse does not mean that treatment was a failure. Rather, it can be viewed as a bridge to the provision of new information and an opportunity for emotional and intellectual growth.

A body of knowledge is emerging that focuses on the problems of relapse. Programs need to be sensitive to the warning signs of relapse, strategies (such as stress management) to manage the prolonged abstinence syndrome, and strategies to prevent relapse. For instance, clients should be provided with opportunities to discuss the emotional, behavioral, and environmental stimuli that were associated with their drug use and to develop strategies to counteract these triggering factors. Two elements of relapse prevention are the preparation of a recovery plan, often called aftercare planning, and the client's continued program affiliation after he or she has completed primary treatment. Many continuing care programs have specialized groups for relapse prevention, while other specialized groups focus on making the transition from intensive treatment to a lower level of care.

### Multifamily Groups

Like their AOD-abusing family members, families can benefit from group therapy with other families. In this setting, families learn that they are not alone in their present struggles; they are assisted in fostering expectations that treatment will work and are aided in developing solutions to problems. A series of planned presentations is often a component of multifamily group therapy.

### Psychiatric Interventions and Services for Dually Diagnosed Individuals

Dual diagnosis or dual disorder are new terms that refer to the coexistence of AOD abuse and psychiatric disorders. A complete assessment will help establish whether a client's disorder is primary to, secondary to, or independent of another existing disorder.

The decision about whether to treat the AOD abuse or the psychiatric disorder(s) first is a difficult one. The general rule is to immediately treat the disorder that is most acute in presentation, that most interferes with present function, that immediately threatens the client's life, or that has an organic origin and can be medically treated. Other circumstances must be considered when deciding whether two disorders, such as AOD abuse and major depression, can be treated concurrently. Treatment planning, consultation, and continued assessments can help address these decisions.

Coexisting psychiatric disorders can interfere with AOD abuse treatment, and if they are left untreated, the client is more vulnerable to relapse. AOD treatment staff should be able to identify coexisting psychiatric disorders and either treat them or provide appropriate referrals for treatment. A consultant may be hired to conduct mental health assessments, or the client may be referred to an outpatient mental health program for evaluation. It is important that staff be aware of the special problems of the person who is dually diagnosed with AOD abuse and a mental disorder. Gathering and sharing clinical data, formulating a diagnosis, and planning intervention for these clients with special needs should be conducted by a treatment team of AOD treatment staff and mental health personnel. Staff should also be aware that some severely ill, dually diagnosed patients tend to be fragile. Transitional confrontational AOD abuse treatment techniques are counterproductive with this group and may exacerbate the concomitant disorder.

Pharmacotherapy for AOD-abusing clients must be accompanied by close observation and monitoring of target symptoms.

### Self-Help

Self-help meetings that are appropriate for the age, gender, and culture of clients are frequently of therapeutic benefit. These meetings, which can be utilized during and following primary treatment, are valuable adjuncts to outpatient services for the client during the recovery process. Self-help groups offer positive role models, new friends who are learning to enjoy life free from AODs, people celebrating sober living, and a place to learn how to cope with the stresses and strains of life. A 12-step model is the most common structure of a self-help approach, but others, such as Rational Recovery and religious programs, may be appropriate.

### Intervention

In AOD abuse treatment, the term "intervention" refers to an effort by family, friends, or others, along with professionals, aimed at intervening in the progression of an individual's AOD abuse and encouraging her or him to enter treatment. The most commonly used intervention was developed by Vernon Johnson and popularized by the Johnson Institute (Johnson, 1986). The intervention process focuses on convincing individuals that they have an AOD problem, helping them recognize the need for treatment and, eventually, changing their behavior.

Interventions typically are conducted in a carefully rehearsed and controlled meeting with the client, significant others, and perhaps a treatment professional. Interventions that do not include a professional may also be successful. During this meeting, members of the group express their concerns and feelings to the individual about his or her substance use. The goals of intervention are to alert the individual to the perceptions and concerns of the important people in the individual's life regarding her or his AOD use, and to convince the individual that the next step is to receive a formal screening and assessment by appropriate professionals.

Interventions can be powerful and effective tools for motivating an individual to enter treatment and for overcoming the denial of family and others about the individual's AOD problems. Moreover, interventions can take the form of social or institutional leverage. For example, pressure from the courts, probation officers, employers, schools, and families can be used to encourage the resistant individual to seek treatment.

Caution should be exercised when interventions are conducted by professionals who are also employees of the treatment program. Such a situation may discourage objectivity on the part of the intervention specialist, who may be overly focused on referring a client to his or her treatment program.

### Educational or Vocational Services

Increasingly, vocational training, general equivalency diploma programs, and job readiness training are being added to treatment programs, because of the needs of many clients to enter the job market. If programs do not offer these services themselves, they may link up with community agencies that can provide them.

## Treatment in Criminal Justice Settings

Effective treatment is being provided to offenders in the justice systems of some jurisdictions. Referrals to treatment as part of the social services offered by the probation or other corrections agency is standard practice in many locations. Assignment to a special AOD caseload as part of an intensive probation sentence is also becoming more commonplace.

### Residential Criminal Justice Programs

Community-based, residential programs are available as sanctioning options in many communities. Their use is growing, particularly as an alternative to revocation for probation and parole violators. Residential facilities can vary considerably in size, ranging from small halfway houses for 20 to work-release facilities that house several hundred offenders. The names of these programs vary as well. Depending on the jurisdiction, intended population, and purpose, the residential programs may be called: diversion centers, prerelease centers, halfway houses, work houses, restitution centers, and reentry houses. The facilities can be managed by the sheriff, community corrections officials, the probation agency, private contractors, the parole agency, or the State corrections agency.

Treatment can be effectively provided in any of these programs. Whatever the setting, these treatment programs have some common characteristics:

- Their mission is to provide control and structure in settings that are less restrictive and less costly than either long-term residential treatment or incarceration, but that can still provide some measure of incapacitation.
- The goals for the offender-client are short-term, involving behavior change that can be initiated while the offender is in the setting and continued after he or she leaves and is on the road to rehabilitation.
- The programs incorporate a treatment plan and provide for case management, treatment, and employment and education services.

The offender in these settings must participate in treatment, must work or attend school outside, and must manage money to pay rent and other obligations such as restitution and child support. Some programs offer additional services to enable the offender to obtain a general equivalency diploma and acquire vocational and general life skills.

AOD abuse treatment is much more likely to succeed for offender-clients if all of these community-based facilities make available an array of services, including education, job training, opportunities for spiritual growth and development, and training in life skills. Programs should emphasize planning for relapse prevention and aftercare (care that continues after discharge from the treatment program). Many programs offer aftercare themselves. Offenders who complete the program can come back after discharge for continuing care or to attend Alcoholics Anonymous (AA) or Narcotics Anonymous (NA) meetings that are part of the treatment program. All continuing care plans, however, should link offenders with community resources that can be used to help them maintain drug-free lives.

### Treatment Within Probation and Parole Supervision

Probation and parole agencies are faced with increasing numbers of offenders under supervision who have been ordered to participate in outpatient AOD abuse treatment but for whom no treatment slots are immediately available. Many agencies have chosen to offer AOD abuse treatment within their own agencies. To this end, the agencies have secured training for their officers to become certified counselors and have begun to provide outpatient treatment of various intensities for the offenders under their supervision.

Having treatment services available onsite increases the ability of the agency and its regular agents to direct offenders into treatment in the absence of a court order: The treatment can be part of the overall supervision strategy. It can also be cost effective for the agency (or the court), since fees do not have to be paid to outside service providers.

There are those both in criminal justice and in the treatment community who question the wisdom of this approach. If the offender-client views the agency primarily as a punitive law enforcement organization, treatment can be difficult, and few such agencies can offer the range of kinds of treatment services that are needed. Some in the criminal justice system also take the view that corrections and the courts ought to be advocates for increased treatment opportunities in the community for everyone rather than taking on the responsibility of making up for the insufficient treatment on the outside by providing it inhouse.

### Specialized Caseloads

In some jurisdictions, probation and parole agencies have responded to the increasing numbers of AOD-abusing offenders under supervision by creating specialized caseloads that group offenders according to a common characteristic or need for purposes of supervision. (As indicated earlier, specialized caseloads have been created to handle a wide variety of types of offenders.) Several types of specialized drug-offender caseloads have been established in jurisdictions around the country, and their use is growing. In some agencies, they are used in conjunction with agency-provided treatment services; in others, the caseloads are intended for offenders who are receiving treatment elsewhere in the community or who are in aftercare.

AOD abuse treatment is much more likely to succeed for offender-clients if all of these community-based facilities make available an array of services, including education, job training, opportunities for spiritual growth and development, and training in life skills.

Specialized caseloads have several common characteristics:

- A probation or parole officer providing the supervision who has the training needed to understand and respond to the needs of the offender-clients;
- Manageable client-to-officer ratios;
- A case plan, developed as part of the presentence or preparole investigation, that is adjusted regularly by the supervising officer;
- A focus on drug offenders;
- Case management, based on the agency's classification process, which is used consistently;
- Assessment for treatment provided by someone other than a probation officer, preferably before sentencing or parole; and
- The ability to call upon other professionals -- such as doctors, psychologists and other mental health professionals, teachers, job trainers, and financial needs consultants -- for additional assistance or services.

The best officers to handle these caseloads are those who understand the process of linking a variety of services together through case management and who can make connections to other professionals in the community for assistance.

Probation and parole officers responsible for specialized caseloads must have administrative support and the backing of their supervisors. The work is very draining, and many officers experience burnout as a result of their attempt to see that the needs of everyone in the caseload are met. The issue of staff burnout should be addressed as part of the program's overall design. That design should include ongoing training and support for officers.

The best officers to handle these caseloads are those who understand the process of linking a variety of services together through case management and who can make connections to other professionals in the community for assistance.

### Day Reporting Centers

A typical day reporting center is a facility for people who are permitted to live at home, but required by the terms of their probation or parole to be at the facility for a specified period each day.

Some day centers function primarily as staging areas from which offenders are sent out in work crews to perform manual labor in the community: cleaning highways, painting schools, and the like. Others offer chiefly educational opportunities. In many jurisdictions, however, day centers have become day treatment centers whose primary mission is to provide outpatient AOD abuse treatment of various intensities. That treatment may be provided by public or private treatment agencies, or by staff of the correctional agency. Day centers can, of course, offer a combination of these activities plus additional ones.

### Home Confinement

Home confinement can be ordered as an accompanying condition with any of the other nonresidential programs described here. The offender must remain within his or her home except for the specific times or activities permitted by the court or paroling authority. Home confinement or curfews are often monitored by means of electronic devices that permit parole or probation agents to verify their presence in (or detect their absence from) the house.

Both home confinement and day reporting centers provide significant restrictions on offenders' liberty and opportunity to commit crime, but are not as restrictive or punitive as a residential program or incarceration. At the same time, they permit the offender-client access to a wider array of treatment options than might be available in a residential correctional setting.

### Self-Help and Support Groups

An important adjunct to treatment is the self-help group, including 12-step programs. Self-help groups, however, are not treatment programs. The best known are Alcoholics Anonymous, Narcotics Anonymous, and Cocaine Anonymous. Many treatment programs are based on what is called the 12-step model of treatment, and attendance at 12-step programs is required of people in treatment. All 12-step programs are modeled after the earliest -- AA -- which is a spiritually based program of recovery. Members "work" each of the 12 steps, which means making each step an inherent part of one's life. Persons who have difficulty with the spiritual basis of AA may prefer other self-help groups such as Rational Recovery or Women for Sobriety. Self-help groups are sometimes established based on ethnicity or gender. No matter who belongs to them, self-help groups are separate from either treatment or the criminal justice system, and they are operated by their members.

In the early years of efforts to overcome alcohol and drug abuse, the self-help groups, particularly AA, were the only resource available to persons with AOD abuse problems, and they are still recognized by virtually all treatment programs as a very significant and necessary adjunct to treatment.

The criminal justice system has recognized the importance of AA, NA, and the others. Many judges require offenders to attend them as a condition of their sentences; parole boards often require attendance as a condition of parole release. In a few localities, AA and NA have allowed monitors to sit outside to ensure that offenders attend meetings. AA or other 12-step groups can be provided in a justice institution or community-based facility in conjunction with treatment or as part of the recovery plan.