# Appendix E—Field Reviewers

- Robert E. Anderson
- Director
- Criminal Justice Programs
- National Association of State Alcohol and Drug Abuse

- Mary Jane Argento, Ph.D.
- Norman Alcohol and Drug Treatment Center
- Griffin Memorial Hospital
- Oklahoma Department of Mental Health and Substance Abuse Services

- Richard Asarian, Ph.D.
- Director/Psychologist
- Mon-Yough Ielase Institute
- Pittsburgh, Pennsylvania

- W. Chester Bell, M.P.A.
- Associate Executive Director
- Stewart Marchman Center
- Daytona Beach, Florida

- Stephen A. Bocian
- Executive Director
- Governor's Office of Justice Assistance
- Baltimore, Maryland

- Dan Cain
- Executive Director
- Eden Programs, Inc.
- Minneapolis, Minnesota

- Matthew Cassidy
- Associate Executive Director
- EAC, Inc.
- Carle Place, New York

- Sandra Clunies, M.S., N.C.A.D.C.
- Public Health Advisor
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Lori-Ann Costantino
- Executive Director
- Bridges of America
- Florida Alcohol and Drug Abuse Association
- American Correctional Association

- Mark Cunniff
- Executive Director
- National Association of Criminal Justice Planners

- Peter J. Delany, D.S.W.
- Social Science Analyst
- Division of Clinical Research
- National Institute on Drug Abuse

- Mark P. Fontaine, M.S.W., C.A.P., C.C.J.A.P.
- Assistant Director
- Florida Alcohol and Drug Abuse Association
- Tallahassee, Florida

- Leon Gillis, III
- Executive Director
- Anti-Recidivist Effort, Inc.
- Daytona Beach, Florida

- R. John Gregrich
- (Acting) Deputy for Demand Reduction
- Office for National Drug Control Policy
- Executive Office of the President

- Donald Lee Harris, Jr.
- Director of Field Services
- Tennessee Department of Corrections

- Walter Helton, M.Div.
- Executive Director
- The Recovery Partnership, Inc.
- Raleigh, North Carolina

- Jeff A. Hoffman, Ph.D.
- Vice President of Operations
- Center for Drug Treatment and Research
- KOBA Institute
- Washington, D.C.

- Dennis A. Humphrey, Ed.D.
- Executive Director
- Massachusetts Committee on Criminal Justice

- Robbie M. Jackman, M.S.S.W.
- Assistant Commissioner
- Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health

- Nolan E. Jones, Ph.D.
- Director
- Justice and Public Safety
- National Governor's Association

- James Kendrick, M.A., C.S.W.
- Director
- Specialty Program in Alcohol and Drug Abuse
- University Substance Abuse Clinic

- Ellsworth Hall
- Western Michigan University
- Kalamazoo, Michigan

- Geoffrey Laredo, M.P.A.
- Senior Program Analyst
- Office of the Administrator
- Office of Policy and Program Coordination
- Division of Planning and Policy Implementation
- Substance Abuse and Mental Health Services Administration

- Linda Loffredo
- Education Associate
- Office of the Deputy Chancellor
- New York City Board of Education

- Doris L. MacKenzie, Ph.D.
- Research Scholar
- Department of Criminal Justice and Criminology
- University of Maryland
- College Park, Maryland

- Jane H. Martin, M.B.A.
- Director
- Risk Reduction Programs
- Substance Abuse Services Section
- Division of Mental Health, Mental
- Retardation, and Substance Abuse
- Department of Human Resources
- Atlanta, Georgia

- Sue Martone, B.A.S.W., M.P.A.
- Legislative Analyst
- Office of the Administrator
- Substance Abuse and Mental Health Services Administration

- James C. May, Ph.D.
- Substance Abuse Director
- City of Richmond Department of Mental Health, Mental Retardation, and Substance Abuse Services
- Richmond, Virginia

- Roberta Messalle
- Senior Advisor
- Criminal Justice Linkages
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Harry W. Moffett
- Senior Human Services Specialist
- Department of Health and Rehabilitation Services
- Tallahassee, Florida

- Mickey M. Neel, N.C.A.D.C., N.C.A.C.II
- Texas Department of Criminal Justice
- Community Justice Assistance Division

- Richard J. Nimer, M.A., C.J.C.A.P.
- Correctional Programs Administrator
- Florida Department of Corrections

- Margo L. Parisi, M.S.S.W.
- Executive Director
- Drug Abuse Comprehensive Coordinating Office
- Tampa, Florida

- Roger H. Peters, Ph.D.
- Assistant Professor
- Florida Mental Health Institute
- Department of Law and Mental Health
- University of South Florida
- Tampa, Florida

- Sheryl Pimlott, M.S.W.
- Project Director
- Project Transition
- Women and Infants at Risk
- Michigan Department of Corrections

- Nancy G. Radford, M.C.J., C.C.J.A.P., C.A.A.P.
- Associate Executive Director
- River Region Human Services, Inc.
- Jacksonville, Florida

- Marilyn Rice, M.A., M.P.H., C.H.E.S.
- Project Director
- National Resource Center for the Prevention of Perinatal Abuse of Alcohol and Other Drugs
- Center for Substance Abuse Prevention

- Barbara T. Roberts, Ph.D.
- Public Health Advisor
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment

- Marilyn McCoy Roberts
- Deputy Director, Washington Office
- National Center for State Courts

- Mark Schuettinger, L.S.A.C.
- Program Coordinator
- Amity, Inc.
- Rayson, Arizona

- Mary Ann Shaening, Ph.D.
- Director
- Shaening and Associates
- Santa Fe, New Mexico

- Steven J. Shapiro
- Public Health Advisor
- Division of National Treatment Demonstrations
- Criminal Justice Systems Branch
- Center for Substance Abuse Treatment

- Rose Soo Hoo, M.S.W., M.B.A.
- Administrator
- King County North Rehabilitation Facility
- Washington State Council on Alcohol and Drug Dependency

- Geraldine Sylvester
- Director
- New Hampshire Office of Alcohol and Drug Abuse

- Sushma D. Taylor, Ph.D.
- Executive Director
- Center Point, Inc.
- San Rafael, California

- Barbara Hanson Treen
- Commissioner
- New York State Board of Parole

- Stephen K. Valle, Sc.D., M.B.A.
- President and CEO
- Right Turn, Inc. and Valle Management Associates
- Lynn, Massachusetts

- Gerald L. Vigdal, M.S.W., B.C.D.
- Director
- Office of Drug Abuse
- Division of Program Services
- Wisconsin Department of Corrections

- Cheryl Clark Walker, M.P.A.
- Program Consultant
- Substance Abuse Program Section
- Michigan Department of Corrections