# Appendix D—Federal Resource Panel

- Robert Anderson
- Director
- Criminal Justice Services
- National Association of State Alcohol and Drug Abuse Directors

- Robert B. Aukerman
- Director
- Alcohol and Drug Abuse Division
- Colorado Department of Health

- Duiona R. Baker, M.P.H.
- Public Health Advisor
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Virginia Brooks Baldau
- Director
- Research Applications and Training Division
- National Institute of Justice
- U.S. Department of Justice

- Steve Bocian
- Deputy Director
- Governor's Office of Justice Assistance
- Baltimore, Maryland

- Jim Brennan
- Staff Associate
- National Association of Social Workers

- Fulton Caldwell, Ph.D.
- Health Scientist Administrator
- National Institute on Alcohol Abuse and Alcoholism

- Diane Canova, J.D.
- Executive Director
- Therapeutic Communities of America
- Arlington, Virginia

- Judge Elbridge Coochise
- President
- National American Indian Court
- Judge Association
- Northwest Intertribal Court System
- Edmonds, Washington

- Mark Cunniff
- Executive Director
- National Association of Criminal Justice Planners

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Peter Delany, M.S.W.
- Project Officer
- Treatment Research Branch
- National Institute on Drug Abuse

- Richard Dembo, Ph.D.
- Professor of Criminology
- University of South Florida
- Tampa, Florida

- John Gregrich
- Senior Policy Analyst
- Office for National Drug Control Policy
- Executive Office of the President

- James Inciardi, Ph.D.
- Professor and Director
- Center for Drug and Alcohol Studies
- University of Delaware
- Newark, Delaware

- Nolan Jones, Ph.D.
- Director of Justice and Public Safety
- National Governor's Association

- Sandra H. Kerr
- Public Health Analyst
- Division of STD/HIV Prevention
- Behavior and Prevention Research Branch
- National Center for Prevention Services
- Centers for Disease Control and Prevention

- Charlene Lewis, Ph.D.
- Chief
- Program Evaluation Branch
- Office of Scientific Analysis and Evaluation
- Center for Substance Abuse Treatment

- Anna Marsh, Ph.D.
- Associate Director for Evaluation
- Office of Applied Studies
- Center for Substance Abuse Treatment

- Ann McDiarmid, Esq.
- Community Corrections Specialist
- National Institute of Corrections

- Peggy McGarry
- Senior Associate
- Center for Effective Public Policy
- Washington, D.C.

- Roberta Messalle
- Public Health Advisor
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Marilyn Rice, M.A., M.P.H., C.H.E.S.
- Deputy Director
- National Resource Center for the Prevention of Perinatal Abuse of Alcohol and Other Drugs

- Barbara Roberts, Ph.D.
- Policy Analyst
- Demand Reduction Office
- Office for National Drug Control Policy
- Executive Office of the President

- Marilyn McCoy Roberts
- Senior Staff Associate
- National Center for State Courts

- Steven J. Shapiro
- Public Health Advisor
- Criminal Justice Branch
- Division of National Treatment Demonstrations
- Center for Substance Abuse Treatment

- Brenda Smith, Esq.
- Senior Council/Economic Security
- National Women's Law Center

- Philip Toelkes
- Program Manager
- State Justice Institute

- Steven Valle, Sc.D., M.B.A., N.C.A.C.
- National Association of Alcoholism and Drug Abuse Counselors

- Gerald L. Vigdal, M.S.W., B.C.D.
- Office Director
- Office of Drug Abuse
- Division of Program Services
- Wisconsin Department of Corrections

- Ellen Weber, Esq.
- Legal Counsel
- Legal Action Center

- Beth Weinman
- National Drug Abuse Coordinator
- Psychology Branch
- Federal Bureau of Prisons

- Cecelia Willis, M.D.
- National Black Alcoholism Council

- John Zachariah
- Regional Administrator
- American Correctional Association