# Appendix A -- Bibliography

Austin, J., Bloom, B., and Donahue, T. Female Offenders in the Community: An Analysis of Innovative Strategies and Programs. San Francisco: National Council on Crime and Delinquency. 1992.
Bureau of Justice Statistics, U.S. Department of Justice. Felony Sentences in State Courts. 1990. Washington, D.C.: Bureau of Justice Statistics, 1991.
Byrne, J.M., Lurigio, A.J., and Baird, C. The effectiveness of the new intensive supervision programs. In Research in Corrections. Washington, D.C.: National Institute of Corrections and the Robert J. Kutak Foundation. 1987.
Center for Substance Abuse Treatment. National Task Force on Correctional Substance Abuse Strategies. TIE Communique. 1993;Spring.
Colorado Department of Health, Alcohol and Drug Abuse Division. Current Findings on Treatment Effectiveness: Questions and Answers. Denver: Colorado Department of Health. 1992.
Colorado House. Bill 91-1173. 1991.
Colorado Story: Colorado's Cooperative Legislative Plan Linking Substance Abuse Treatment With the Criminal Justice System (unpublished paper). Rockville, Maryland: Center for Substance Abuse Treatment. 1993.
Freed, D.J., and Mahoney, B. Between prison and probation: using intermediate sanctions effectively. Judges Journal. 1990;Winter:1-14.
Johnson, V.E. Intervention: How to Help Someone Who Doesn't Want Help. Minneapolis: Johnson Institute Books. 1986.
Keiser, G.M. Presentation for the Community Justice Resource Center. Greensboro, N.C.: Guilford College, March 5. 1991.
McGarry, P. Improving the Use of Intermediate Sanctions: Lessons from the Intermediate Sanctions Project. Washington, D.C.: Center for Effective Public Policy. 1992.
Office of Justice Programs. A Survey of Intermediate Sanctions. Washington, D.C.: U.S. Department of Justice. 1990.
Petersilia, J. Conditions that permit intensive supervision programs to survive. Crime & Delinquency. 1990;36(1):126-145.
Petersilia, J. Expanding Options for Criminal Sentencing. Santa Monica, California: Rand Corp. 1987.
Vidgal, G.L. Comprehensive Assessment, Diagnosis and Classification: Treatment Matching of Substance Abusing Offenders. Madison: Wisconsin Department of Corrections. 1990.
Vigdal, G.L. Summary of Uniform Substance Abuse Screening Battery. Madison: Wisconsin Department of Corrections. 1990.