# Consensus Panel

Chairs
- Ken C. Winters, Ph.D.
- Director
- Center for Adolescent Substance Abuse
- University of Minnesota
- Minneapolis, Minnesota
- Jonathan M. Zenilman, M.D.
- Assistant Professor
- Division of Infectious Diseases
- Johns Hopkins University School of Medicine
- Baltimore, Maryland

Facilitators
- Michele D. Kipke, Ph.D.
- Associate Director
- Division of Adolescent Medicine
- Children's Hospital of Los Angeles
- Los Angeles, California
- Juan Carlos Lovelace, Ed.D.
- Executive Assistant
- Child and Youth Services Administration
- District of Columbia Commission on Mental Health Services
- Florence Stroud, M.P.H., B.S.N.
- Senior Deputy Director of Health
- for Community Health Programs
- San Francisco Department of Public Health

Workgroup Members
- Margaret Brooks, J.D.
- Consultant
- Montclair, New Jersey
- Lynn M. Campanario
- Senior Community Epidemiologist STD/HIV Clinic
- Fulton County Health Department
- Atlanta, Georgia
- Barbara Chaffee, M.D.
- United Health Services
- Binghamton, New York
- Yvonne Frazier
- Associate Director
- Grants and AIDS Activities
- Community Substance Abuse Services
- Department of Public Health
- City and County of San Francisco
- Nancy Jainchill, Ph.D.
- Principal Investigator
- Center for Therapeutic Community Research
- National Development and Research Institutes
- New York, New York
- Lee A. Jenkins
- Supervisor
- Street Team AIDS Risk Reduction
- Communicable Disease Branch
- Georgia Department of Human Resources
- Atlanta, Georgia
- Rolando T. Martinez, M.S.W., B.C.D.
- Director of Social Work
- St. Francis Hospital and Medical Center
- Hartford, Connecticut
- Ann Elizabeth Medinger, M.D.
- Associate Professor of Medicine and Physiology
- George Washington University School of Medicine
- Washington, D.C.
- Eileen C. Napolitano
- Assistant Chief
- Sexually Transmitted Disease Control Program
- New Jersey Department of Health
- Trenton, New Jersey
- Sheryl S. Palmer, M.A.
- HESS Coordinator
- Treatment Alternatives for Special Clients, Inc.
- Chicago, Illinois
- John Rullan, M.D.
- Executive Director
- Central Office for AIDS Affairs and Communicable Disease
- Puerto Rico Department of Health
- Kevin M. Shipman, M.H.S.
- Public Health Educator
- Alcohol and Drug Abuse Services Administration
- Washington, D.C.
- James P. Simmons
- Consultant
- Potomac, Maryland
- Wayne Wiebel, Ph.D.
- Associate Professor
- School of Public Health
- University of Illinois at Chicago