# What Is a TIP?

CSAT Treatment Improvement Protocols (TIPs) are prepared by the Quality Assurance and Evaluation Branch to facilitate the transfer of state-of-the-art protocols and guidelines for the treatment of alcohol and other drug (AOD) abuse from acknowledged clinical, research, and administrative experts to the Nation's AOD abuse treatment resources.

The dissemination of a TIP is the last step in a process that begins with the recommendation of an AOD abuse problem area for consideration by a panel of experts. These include clinicians, researchers, and program managers, as well as professionals in such related fields as social services or criminal justice.

Once a topic has been selected, CSAT creates a Federal resource panel, with members from pertinent Federal agencies and national organizations, to review the state of the art in treatment and program management in the area selected. Recommendations from this Federal panel are then transmitted to the members of a second group, which consists of non-Federal experts who are intimately familiar with the topic. This group, known as a non-Federal consensus panel, meets in Washington for 5 days, makes recommendations, defines protocols, and arrives at agreement on protocols. Its members represent AOD abuse treatment programs, hospitals, community health centers, counseling programs, criminal justice and child welfare agencies, and private practitioners. A chair for the panel is charged with responsibility for ensuring that the resulting protocol reflects true group consensus.

The next step is a review of the proposed guidelines and protocol by a third group whose members serve as expert field reviewers. Once their recommendations and responses have been reviewed, the chair approves the document for publication. The result is a TIP reflecting the actual state of the art of AOD abuse treatment in public and private programs recognized for their provision of high quality and innovative AOD abuse treatment.

This TIP, titled Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases, addresses the twin epidemics of substance abuse and infectious diseases. Service providers from many disciplines and across many systems and agencies are increasingly encountering individuals with AOD abuse problems, which place them at higher risk for acquiring infectious diseases. The TIP presents two screening instruments - one for AOD abuse and one for infectious diseases - that were designed to be able to be rapidly administered by a wide range of providers and relatively simple to score and interpret. The instruments are flexible and applicable to diverse populations. The TIP describes considerations in the development of these instruments and offers guidelines for their use in field tests. Guidelines for training staff in the use of these instruments are also presented, and legal and ethical concerns, especially in the area of confidentiality, are discussed.

This TIP represents another step by CSAT toward its goal of bringing national leadership to bear in the effort to improve AOD abuse treatment.