# Appendix E - Field Reviewers

- Lynn M. Campanario
- Senior Community Epidemiologist
- Fulton County Health Department
- STD/HIV Clinic
- Atlanta, Georgia

- Barbara Chaffee, M.D.
- United Health Services
- Binghamton, New York

- Shirley Clark, M.M.H.
- Health Scientist Administrator
- Executive Office Center
- Center for Medical Effectiveness Research
- Agency for Health Care Policy and Research

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Ingrid Davis
- Treatment Policy Consultant
- Center for Substance Abuse Services
- Michigan Department of Health
- Lansing, Michigan

- Maureen Deely, R.N.
- Homecare Coordinator
- AIDS Outreach and Education
- Montgomery County Health Department
- Silver Spring, Maryland

- Sherry Deren, Ph.D.
- Director
- Institute for AIDS Research
- National Development and Research Institutes, Inc.
- New York, New York

- Kathy Donner
- Program Consultant
- Social and Rehabilitation Services
- Alcohol and Drug Abuse Services
- Topeka, Kansas

- John C. Fitzpatrick
- Director of Alcoholism and Substance Abuse Services
- Sunset Park Family Health Center of the Lutheran Medical Center
- Brooklyn, New York

- Yvonne Frazier
- Associate Director
- Grants and AIDS Activities
- Community Substance Abuse Services
- Department of Public Health
- City and County of San Francisco

- Frederick B. Glaser, M.D., F.R.C.P.(C)
- Director
- Substance Abuse Center
- University of Medical Center
- Ann Arbor, Michigan

- Terri Goens
- Program Manager
- Office of Substance Abuse and General Mental Health
- Arizona Department of Health Services

- Jane Grimstad, Ph.D.
- Scientist
- Center for Health Policy and Program Evaluation
- University of Wisconsin
- Madison, Wisconsin

- Rick Hawks, Ph.D.
- Psychologist
- Weber County Department of Substance Abuse
- Ogden, Utah

- Thomas W. Hester, M.D.
- Acting Deputy Division Director
- Substance Abuse Services Section
- Division of Mental Health, Mental Retardation, and Substance Abuse
- Atlanta, Georgia

- Nancy Jainchill, Ph.D.
- Principal Investigator
- Center for Therapeutic Community Research
- National Development and Research Institutes
- New York, New York

- Lee A. Jenkins
- Supervisor
- Street Team AIDS Risk Reduction
- Communicable Disease Branch
- Georgia Department of Human Resources

- Carol Jordan, R.N., M.P.H.
- Administrator
- STD/HIV Program
- Montgomery County Health Department
- Silver Spring, Maryland

- Ruth H. Carlsen Kahn, D.N.Sc., R.N.
- Health Professions Education Specialist
- Division of Medicine
- Bureau of Health Professions
- Health Resources and Services Administration

- Michele D. Kipke, Ph.D.
- Associate Director
- Division of Adolescent Medicine
- Children's Hospital of Los Angeles

- Dave Knott, Ph.D., M.D.
- Program Director
- Alcohol and Drug Dependence Unit
- Memphis Mental Health Institute
- Memphis, Tennessee

- Jeffrey N. Kushner
- Director
- Office of Alcohol and Drug Abuse Programs
- Salem, Oregon

- Alan R. Lifson, M.D., M.P.H.
- Associate Professor
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- Minneapolis, Minnesota

- Juan Carlos Lovelace, Ed.D.
- Executive Assistant
- Child and Youth Services Administration
- District of Columbia Commission on Mental Health Services

- Rolando T. Martinez, M.S.W., B.C.D.
- Director of Social Work
- St. Francis Hospital and Medical Center
- Hartford, Connecticut

- Robin R. Mathews, M.S.W., M.A., L.S.W.
- Research and Evaluation Administrator
- Ohio Department of Alcohol and Drug Addiction Services
- Columbus, Ohio

- Ann Elizabeth Medinger, M.D., F.A.C.P.
- Associate Professor of Medicine and Physiology
- George Washington University School of Medicine
- Washington, D.C.

- David Metzger, Ph.D.
- Director
- Opiate/AIDS Research Division
- Center for Studies of Addiction
- University of Pennsylvania
- Philadelphia, Pennsylvania

- Eileen C. Napolitano
- Assistant Chief
- Sexually Transmitted Disease Control Program
- New Jersey Department of Health

- Sheryl S. Palmer, M.A.
- HESS Program Coordinator
- Treatment Alternatives for Special Clients
- Chicago, Illinois

- Joe Patterson, M.A., C.S.A.C.
- Clinical Director
- Sunburst Treatment Services, Inc.
- Chandler, Arizona

- Jerome Platt, Ph.D.
- Professor and Director
- Division of Addiction Research and Treatment
- School of Medicine
- Hahnemann University
- Philadelphia, Pennsylvania

- Elizabeth Rahdert, Ph.D.
- Research Psychologist
- Clinical and Experimental Therapeutics Branch
- Division of Clinical Research
- National Institute on Drug Abuse

- Gary Remafedi, M.D., MPH
- Director
- Youth and AIDS Projects
- University of Minnesota Hospital and Clinics
- Minneapolis, Minnesota

- John Rullan, M.D.
- Executive Director
- Central Office for AIDS Affairs and Communicable Disease
- Puerto Rico Department of Health

- Jane Schwebke, M.D.
- Program Director
- STD/HIV Programs
- Chicago Department of Health

- Ann Shemo, D.O., M.P.H.
- Director/Public Health Physician
- Division of Communicable Disease Prevention
- Department of Health
- Harrisburg, Pennsylvania

- Kevin M. Shipman, M.H.S., C.A.C.
- Public Health Educator
- District of Columbia Alcohol and Drug Abuse Services Administration

- James P. Simmons, Ed.D.
- Executive Director
- SERVON, Inc.
- Potomac, Maryland

- Patricia Ann Smith, R.N.
- Adult Nurse Practitioner
- Sexually Transmitted Disease Clinic
- Druid Health District
- Baltimore, Maryland

- Jack B. Stein, L.C.S.W.
- Director
- Center for HIV and Substance Abuse Training
- Arlington, Virginia

- Florence Stroud, M.P.H., B.S.N.
- Senior Deputy Director of Health
- for Community Health Programs
- San Francisco Department of Public Health

- Linda Washington, M.S.N., R.N., C.S.P.
- Psychiatric Nurse Clinical Specialist
- Outpatient Addictions Services
- Montgomery County Department of Addictions, Victims, and Mental Health Services
- Silver Spring, Maryland

- Wayne Wiebel, Ph.D.
- Associate Professor
- School of Public Health
- University of Illinois at Chicago
- Benjamin Williams, L.C.S.W.

- Clinical Resources Coordinator
- Florida Alcohol and Drug Abuse Program Office
- Tallahassee, Florida

- Ken Willinger, Ph.D.
- Clinical Psycologist
- Alcohol and Drug Abuse Division
- Department of Health
- Honolulu, Hawaii

- Ken C. Winters, Ph.D.
- Director
- Center for Adolescent Substance Abuse
- University of Minnesota
- Minneapolis, Minnesota

- Jonathan M. Zenilman, M.D.
- Assistant Professor
- Division of Infectious Diseases
- Johns Hopkins University School of Medicine
- Baltimore, Maryland